# Description of Evidence

## A Why Treat Overweight and Obesity?

### Blood Pressure

To evaluate the effect of weight loss on blood pressure and hypertension, 76 articles reporting randomized controlled trials (RCTs) were reviewed. Of these, 60 were lifestyle trials that studied diet and/or physical activity and 16 were pharmacotherapy trials of anorexiants. The 60 lifestyle trials were: [346–352, 354–380, 352, 354–380, 405, 470, 473, 484, 490, 674–694,] The 16 articles on pharmacotherapy trials of anorexiants were: [386–395, 512, 695–699,]

#### Lifestyle Trials

Of the 60 lifestyle trials reviewed, 35 were accepted and 25 were not included for these reasons:

- the no-treatment control group also lost weight; [470, 473, 484, 490, 675–680, 683, 684, 688, 690, 692, 693]
- there was no appropriate control group; [687]
- the dropout rate was more than 35 percent; [685, 686]
- the results were not compared according to randomized treatment assignments; [681]
- the population at baseline was not overweight; [689–691]
- blood pressure was not reported as a primary or secondary outcome; [405] or
- the intervention period was less than 4 weeks [674].

#### Pharmacotherapy Trials

Of the 16 pharmacotherapy trials reviewed, 10 were accepted and 6 were not included because:

- the drug that was tested is not recommended for weight loss [695] [ephedrine alone] [696] [a beta-adrenoceptor agonist] [697] [ephedrine combined with caffeine] [698] [testosterone] [699] [cimetidine], or
- only very short-term data are available [512].

### Serum/Plasma Lipids and Lipoproteins

Sixty-five RCT articles were evaluated for the effect of weight loss on serum/plasma concentrations of total cholesterol, low-density lipoprotein cholesterol, very low-density lipoprotein cholesterol, triglycerides, and high-density lipoprotein cholesterol. In 52 of these trials weight loss was induced by various lifestyle modifications, including diet modification and increased physical activity [356, 365, 367–370, 373, 380, 384, 399–406, 412, 431, 433, 434, 440, 446, 447, 469, 470, 473, 475, 484, 490, 677–679, 681, 683–685, 688–690, 693, 694, 700–709].

Thirteen RCT articles were reviewed that considered the effects of pharmacological therapy on weight loss and subsequent changes in total serum cholesterol level [386, 390–393, 395, 407, 408, 696–698, 710, 711].

#### Lifestyle Trials

Of the 52 lifestyle trials:

- 27 RCT articles examined the effect on plasma lipids of weight loss induced by diet alone, i.e., these studies simply included a diet intervention without a formal physical activity program or medications [356, 368–370, 373, 399, 400, 402, 412, 431, 433, 440, 484, 490, 677, 679, 683, 688–690, 693, 701, 702, 704, 706, 708, 709].
- 11 RCT articles examined weight loss induced by increased physical activity alone; [365, 401, 404, 406, 447, 678, 685, 700, 703, 705, 707] and
- 14 RCT articles considered the combination of caloric restriction and physical activity [367, 380, 384, 403, 405, 434, 446, 469, 470, 473, 475, 681, 684, 694].

Of the 52 lifestyle trials reviewed, 14 met the criteria for inclusion [365, 368, 370, 373, 380, 384, 399–406]. The remaining 38 were not considered because:

- The no-treatment control group also lost weight [434, 446, 469, 470, 473, 475, 484, 490, 677–679, 683, 684, 688, 690, 693, 694, 701, 705, 706, 708, 709].
- There was no appropriate control group; [431, 700]
- There was no difference in weight loss between the treatment and control group; [447, 702, 703]
- The dropout rate was more than 35 percent; [685]
- The population was not overweight; [689, 690]
- The results were not reported according to randomized treatment; [681]
- The outcome measures were not reported separately for the overweight and not overweight groups; [440]
- There was no measure of at least one lipoprotein fraction or measure of change in lipids between the beginning and end of treatment; [356, 367, 412, 433, 704] or
- Lipoprotein concentrations could not be determined from the figures in the paper [707], or it was difficult to get precise measures [369].

#### Pharmacotherapy Trials

The effects of pharmacological therapy on weight loss and subsequent changes in total serum cholesterol levels were evaluated by examining 13 RCT articles: 5 on the effect of dexfenfluramine; [386, 390– 393] 2 on fluoxetine; [408, 711] 1 on the combination of phentermine and fenfluramine (phen/fen); [395] 2 on orlistat; [407, 710] 1 on testosterone decanoate; [698] 1 on ephedrine alone or in combination with caffeine; [697] and 1 on a beta adrenoceptor agonist [696]. Of the 13 pharmacotherapy trials reviewed, 8 were accepted and 5 were not considered for these reasons:

- The main outcome of the treatment was not weight loss; [698]
- The drug in question is not currently being recommended for weight loss; [696–698]
- The dropout rate was more than 35 percent; [711] or
- It was a marginal 12-week study [710].

### Impaired Glucose Tolerance and Diabetes

Forty-nine articles on RCTs were reviewed to evaluate the effect of weight loss on fasting blood glucose and fasting insulin [70, 362, 367, 369, 373, 386, 387, 390–393, 403, 404, 408, 412–415, 439, 440, 446, 470, 473, 474, 482, 485, 490, 492, 493, 576, 676–678, 681, 683, 684, 689, 690, 693, 694, 696–698, 700–702, 708, 709, 712]. Studies were conducted in individuals with normal blood glucose levels (fasting plasma glucose < 115 mg/dL [< 6.4mmol/L]) [367, 373, 386, 387, 390–393, 403, 412, 415, 677, 678, 681, 683, 684, 689, 690, 694, 696–698, 700], in individuals with impaired glucose tolerance (fasting plasma glucose of < 140 mg/dL [7.8 mmol/L] or 2 hours postprandial plasma glucose of ≥ 140 to < 200 mg/dL [7.8 to 11.1 mmol/L]) [70, 369], or in individuals with diabetes (fasting plasma glucose of > 140 mg/dL or 2 hours postprandial plasma blood glucose ≥ 200mg/dL) [362, 404, 408, 413, 414, 439, 440, 446, 470, 473, 474, 482, 485, 490, 492, 493, 576, 676, 693, 701, 702, 708, 709, 712].^*^

* The reviewed articles used the “old” definitions of the American Diabetes Association (ADA) for impaired glucose tolerance and diabetes. As of November 1997, the new ADA definitions define “impaired fasting glucose” as those individuals having a fasting plasma glucose of 110 to 125 mg/dL, and “diabetes” as those individuals having a fasting plasma glucose of ≥ 126 mg/dL or 2 hours postprandial plasma glucose of ≥ 200 mg/dL.

#### Lifestyle Trials

Of the 38 trials reviewed on the role of lifestyle in weight loss and subsequent changes in blood glucose levels, 16 were on diet alone [70, 373, 412, 413, 415, 439, 440, 576, 677, 683, 689, 693, 701, 702, 708, 709], 8 dealt with physical activity alone [70, 369, 404. 474 676, 678, 690, 700], 8 focused on diet plus physical activity [70, 362, 403, 446, 470, 473, 681, 684], and 5 examined the role of behavior therapy [367, 482, 485, 490, 493]. One study included diet, behavior therapy and physical activity [694]. One study included diet, behavior therapy and physical activity [694]. One study [414] included diet, behavioral therapy and drug therapy. Of the 38 trials, 9 were accepted, and 29 were not considered for these reasons:

- There was a control group that had a weight loss intervention or there was no difference in weight loss between the treatment and control groups; [439, 446, 470, 473, 474, 482, 485, 490, 492, 493, 576, 676–678, 683, 684, 690, 693, 694, 701, 702, 708, 709]
- The dropout rate was more than 35 percent; [415]
- The results were not reported according to randomized treatment assignments; [681]
- Outcome measures were not reported separately for the obese and nonobese people who lost weight; [440]
- There was no appropriate control group; [700] or
- The population was not overweight [689, 690].

#### Pharmacotherapy Trials

Of the 12 pharmacotherapy trials reviewed, 8 were accepted and 4 were excluded for these reasons:

- The main outcome of the treatment was not weight loss; [698] or
- The drug used is not currently being recommended for weight loss [696–698, 712].

## B What Treatments Are Effective?

### Dietary Therapy

Of the 86 RCT articles evaluated for the effectiveness of dietary therapy on weight loss, 49 were accepted; 37 were not considered for the following reasons:

- Diet alone was not evaluated; [376, 405]
- There was no control group; [442, 446, 675, 676, 680, 683, 686, 688, 693, 702, 709, 713–720]
- There was no appropriate control group; [677, 704]
- The dropout rate was more than 35 percent; [415]
- The weight loss intervention was less than 12 weeks; [402, 474, 477, 576, 674, 708, 714, 721–723]
- The study did not provide specific information to assess the diet; [724] or
- The patients were not overweight [689–691].

### Physical Activity

Twenty-three RCT articles were reviewed for the effect of physical activity on weight loss, body fat distribution (abdominal fat), and fitness level; of these, 13 were accepted and 10 were not considered. The 23 RCTs were: [346, 363, 365, 369, 375, 401, 404, 406, 432, 434, 445–447,474, 475,678, 685, 700, 705, 707, 725–727] Of the 23 RCTs, 11 were conducted on overweight or obese populations with an average body mass index > 25 kg/m^2^ [346, 365, 369, 401, 434, 445–447, 685, 700, 725]. Four RCTs were conducted on an overweight or obese population with an average weight of 120 percent to 160 percent of ideal body weight [363, 406, 432, 475]. One RCT was conducted on obese or overweight populations with a percent of body fat > 25 for men or > 30 for women [678].

Nine RCT articles presented results on men [363, 365, 369, 406, 432, 700, 705, 707, 726], six RCTs were conducted on women [434, 445, 446, 678, 685, 725], and seven RCTs covered both men and women [346, 401, 404, 447, 474, 475, 727].

One RCT article included hypertensive individuals [346], three RCTs included people with type 2 diabetes [404, 446, 474], and one RCT included individuals with hyperlipidemia [685].

Ten RCT articles were not included because:

- The population at baseline was not overweight [705, 727], or it was not clear if the population was overweight; [707, 726]
- The intervention period was less than 12 weeks; [474]
- There was no appropriate control group; [475, 678, 700, 725] and
- The dropout rate was more than 35 percent [685].

### Combined Therapy

Twenty-three RCT articles investigated the effects on body weight of a combination of a reduced-calorie diet with increased physical activity. The control groups used diet alone or exercise alone [346, 365, 375–377, 380, 384, 405, 434, 435, 445, 448, 469–475, 681, 684, 728, 729]. Of the 23, 15 were accepted and 8 were not considered for the following reasons:

- There was no exercise-alone or diet-alone comparison group; [376, 405, 475, 681, 684, 728, 729] or
- The intervention was less than 12 weeks [474].

### Behavior Therapy

#### Additional Benefits Beyond Other Weight Loss Approaches

Thirty-six RCT articles were reviewed to evaluate whether behavior therapy provides additional benefit beyond other weight loss approaches. Of the 36, 4 were accepted and 32 were not considered. The 36 trials were: [350, 373, 376, 379, 395, 399, 400, 412, 414, 415, 436–438, 443, 444, 469, 470, 473, 476,–478, 490, 510, 677, 679, 688, 700,708, 709, 730–736]

Four RCT articles that compared behavior therapy plus another weight loss strategy to that weight loss strategy without behavior therapy, and that met the inclusion criteria, were accepted. Three of the accepted studies compared behavior therapy to a dietary intervention [436, 476, 477]. No studies were found that compared behavior therapy to either exercise or to a combination of diet and exercise. One study was found that compared behavior therapy to drug therapy [478].

Thirty-two of the articles were not considered because:

- Either behavior therapy was not used or it was not possible to ascertain whether it was used; [412, 490, 677, 730]
- Behavior therapy was used either alone or as part of an intervention, but the comparison groups used did not allow for determining the unique effect of behavior therapy; [350, 373, 376, 399, 400, 414, 415, 444, 470, 700, 732, 735] or
- Behavior therapy was integrated into all of the intervention groups, making it impossible to detect the unique effect of behavior therapy [379, 395, 437, 438, 443, 469, 473, 510, 679, 688, 708, 709, 731, 733, 734, 736].

#### Comparison of Behavior Therapy Strategies

Another way to examine the efficacy of behavior therapy in the treatment of obesity is to evaluate studies that compare various behavioral techniques to one another. These studies are primarily from the behavioral psychology literature.

Thirty-one RCT articles were reviewed that compared one or more behavioral interventions [367, 445, 476, 479–495, 632, 680, 694, 737–744]. Most of the trials used a group format and followed subjects over time; three included booster sessions [484, 487, 491]. Twelve of the studies provided 1 year or more of follow-up weights. Most studies lacked a pure, no-treatment, control group. There were limited intervention data on special populations, including various ethnic groups and populations with low income and education. Men and women were well represented. The majority of patients were young and middle-aged adults.

Nine of the trials studied special patient populations: subjects with type 2 diabetes; [482, 485, 489, 490, 492 493, 739] subjects at high risk for coronary artery disease; [484] and subjects with binge eating disorder [494]. Trials with subjects with type 2 diabetes used behavioral approaches to increase adherence to the American Diabetes Association diet and improve glycemic control, rather than to lose weight as the primary objective (although all reported an effect on weight).

Of the 31 articles reviewed, 19 were accepted and the following 12 were not included because:

- The results were not presented by treatment group; [694]
- The dropout rate was more than 35 percent; [445, 632, 742, 744]
- Self-reported body weight was used; [741]
- There was no control group; [680]
- The treatment duration was less than 12 weeks; [737–739, 743] or
- The population was not overweight [740].

### Pharmacotherapy

Forty RCTs evaluated the effect of pharmacotherapy on weight loss. In most studies, advice or behavioral therapy that promoted reduced energy intake and increased physical activity was included in all treatment arms, including the placebo group. The RCTs addressed the following pharmacotherapies: BRL 26830A [696], cimetidine [699], dexfenfluramine [386, 387, 390–393, 414, 478, 506–508, 711, 745, 746], ephedrine [695, 697, 747], fenfluramine [478], fenfluramine and phentermine [395, 514, 748, 749], femox-etine [750], fluoxetine [408, 712, 730, 734, 751, 752], mianserine [753], orlistat [407, 710], phenylpropanolamine [511, 512], phentermine [176, 754], testosterone [698], yohimbine [755], and sibutramine [510]. Most of the patients in these trials weighed more than 120 percent of their ideal body weight or had a BMI of 25 to 30.

RCTs that examined cimetidine, mianserine, yohimbine, testosterone, femoxetine, and BRL 26830A were not considered either because they are not now being studied for obesity treatment or because they are not approved by the Food and Drug Administration (FDA) for obesity treatment. Fluoxetine, and other selective serotonin reuptake inhibitors commonly used for the treatment of depression, have not been approved for use as antiobesity agents. Ephedrine has been tested alone and in combination with caffeine. Although a significant 3.4 kg difference was found at 6 months in patients treated with this combination compared with those on placebo [695], the ephedrine/caffeine combination is not approved by the FDA for use in the United States. In addition, studies with a dropout rate greater than 35 percent were not considered [711]. As of September 1997, two FDA-approved drugs, dexfenfluramine and fenfluramine, were withdrawn from the market by the manufacturer due to an observed association with valvular heart disease in patients taking the combination of phentermine/fenfluramine, or “Redux.” The panel's deliberations on the evidence regarding these drugs are included in the report for informational purposes only.

### Weight Loss Surgery

Fourteen RCTs compared the weight-reducing effect of different surgical interventions [515–522, 524, 692, 706, 733, 756, 757]. One study compared the effectiveness of a very low-calorie diet to surgery [515]. Another study compared the effectiveness of horizontal-banded to vertical-banded gastroplasty in a pretreated, very low-calorie formula diet group [516]. Six studies compared two or more of the following procedures: gastroplasty (vertical or horizontal), gastric bypass, and gastric partitioning [517–522]. Seven studies reported long-term (1 year or more) follow up [515, 517–522]. Two studies looked at comorbidity factors associated with weight loss [517, 519].

Of these 14 RCT studies, the following five were not included because:

- Two studies looked at the effect on weight loss of jejunoileostomy, a procedure that is no longer recommended; they were not included because of the complications associated with this procedure; [692, 706] and
- Three studies compared the use of the gastric balloon to sham procedures; [733, 756, 757] however, this procedure is no longer utilized except in research studies.