# Literature Review

The results of the literature search are provided below in terms of the population (top) and clinical (bottom) portions of the evidence model. A total of 43,627 records were obtained from the search; the following notes the number of records per topic.

Population model search citations by topic area (22,017 total):

cardiovascular disease | 3,675 citations
hypertension | 93 citations
diabetes | 65 citations
dyslipidemia | 73 citations
cardiovascular morbidity and mortality | 225 citations
noncardiovascular morbidity and mortality | 4,272 citations

Clinical model search citations by topic area (11,268 total):

cardiovascular disease | 1,866 citations
hypertension | 616 citations
diabetes | 380 citations
dyslipidemia | 917 citations
cardiovascular morbidity and mortality | 71 citations
noncardiovascular morbidity and mortality | 6,507 citations

The number of citations per topic do not add up to the total citations per top or bottom model or the overall NLM search. The total number includes all of those listed above plus the citations for fitness, weight loss, and abdominal fat.

Evidence Model Questions Population Model (Top)

Arrow Number | Question
1 | Not considered
2 | What is the evidence that relates weight to abdominal fat?
3 | Not considered
4 | What is the evidence that relates abdominal fat to high blood pressure in minority populations?
5 | What is the evidence that relates abdominal fat to dyslipidemia in minority populations?
6 | What is the evidence that relates abdominal fat to diabetes in minority populations?
7 | What is the evidence that relates abdominal fat to cardiovascular disease?
8 | What is the evidence that relates abdominal fat to noncardiovascular mortality and morbidity?
9 | What is the evidence that relates abdominal fat to cardiovascular mortality and morbidity?
34 | What is the evidence that relates weight to high blood pressure in minority populations?
35 | What is the evidence that relates weight to dyslipidemia in minority populations?
36 | What is the evidence that relates weight to diabetes in minority populations?
37 | What is the evidence that relates weight to cardiovascular disease?
38 | What is the evidence that relates weight to noncardiovascular mortality and morbidity?
39 | What is the evidence that relates weight to cardiovascular mortality and morbidity?

Evidence Model Questions Clinical Model (Bottom)

Arrow Number | Question
10 | Not considered
11 | Not considered
12 | What is the evidence that treatment directly affects abdominal fat?
13 | What is the evidence that treatment directly affects weight loss?
14 | What is the evidence directly relating treatment and fitness?
15 | What is the evidence that fitness is directly related to weight loss?
16 | What is the evidence that weight loss directly affects abdominal fat?
17 | What is the evidence that a reduction of abdominal fat is directly related to cardiovascular disease?
18 | What is the evidence that a reduction of abdominal fat is directly related to cardiovascular mortality and morbidity?
19 | What is the evidence that a reduction in abdominal fat directly affects high blood pressure?
20 | What is the evidence that a reduction in abdominal fat directly affects dyslipidemia (cholesterol)?
21 | What is the evidence that a reduction in abdominal fat directly affects glucose tolerance?
22 | What is the evidence that weight loss directly affects high blood pressure?
23 | What is the evidence that weight loss directly affects dyslipidemia (cholesterol)?
24 | What is the evidence that weight loss directly affects glucose tolerance?
25 | What is the evidence that fitness directly affects high blood pressure?
26 | What is the evidence that fitness directly affects dyslipidemia (cholesterol)?
27 | What is the evidence that fitness directly affects glucose tolerance?
28 | What is the evidence that fitness is directly related to noncardiovascular mortality?
29 | What is the evidence that fitness is directly related to cardiovascular mortality and morbidity?
30 | What is the evidence that fitness is directly related to cardiovascular disease?
31 | What is the evidence directly relating weight loss and noncardiovascular mortality and morbidity?
32 | What is the evidence directly relating weight loss and cardiovascular mortality and morbidity?
33 | What is the evidence directly relating weight loss and cardiovascular disease?