# Appendices

I.A.1. Guidelines Development Methodology

I.A.2 Literature Review

II. Description of Evidence

III. Special Populations

IV. Obesity and Sleep Apnea

V. Body Mass Index—How to Measure Obesity

VI. Practical Dietary Therapy Information

VII. Resource List

VIII. Glossary of Terms