# Peer Reviewers

Daleen Aragon—Orlando Regional Healthcare, FL

William Baine—AHRQ, MD

Mary Barton—AHRQ, MD

Mary Blegen—University of California at San Francisco, CA

Barbara Braden—Creighton University, NE

Nancy Bergstrom—University of Texas, Houston, TX

Peter Bruehaus—Vanderbilt University, TN

Helen Burstin—National Quality Forum, DC

Carol Cain—Kaiser Permanente, CA

Carolyn Clancy—AHRQ, MD

Sean Clarke—University of Pennsylvania, PA

Marilyn Chow—Kaiser Permanente, CA

Beth Collins-Sharp—AHRQ, MD

Kathy Crossen—AHRQ, MD

Linda Lindsey Davis—Duke University, NC

Ellen Mockus D’Errico—Loma Linda University, CA

Joanne Disch—University of Minnesota, MN

Anita Hanrahan—Capital Health, Edmonton, Alberta

Aparana Higgins—Booz Allen Hamilton, NY

Kerm Henrickson—AHRQ, MD

Judith Hertz—Northern Illinois University, IL

Ronda Hughes—AHRQ, MD

Rainu Kaushal—Harvard Medical School/Partners, MA

Ron Kaye—FDA, MD

Marge Keys—AHRQ, MD

Christine Kovner—New York University, NY

Jeanette Lancaster—University of Virginia, VA

David Lanier—AHRQ, MD

Elaine Larson—Columbia University, NY

Kathy Lee—University of California at San Francisco, CA

Michael Leonard—Kaiser Permanente, CA

Sally Lusk—University of Michigan, MI

David Meyers—AHRQ, MD

Jack Needleman—University of California at Los Angeles, CA

D.E.B. Potter—AHRQ, MD

Peter Pronovost—Johns Hopkins University, MD

Amanda Rischbieth—Australia

Carol Romano—U.S. Department of Health and Human Services, U.S. Public Health Service, MD

Judy Sangel—AHRQ, MD

Cynthia Scalzi—University of Pennsylvania, PA

Carol Scholle—University of Pittsburgh Medical Center/Presbyterian Hospital, PA

Jean Ann Seago—University of California at San Francisco, CA

Joan Shaver—University of Illinois at Chicago, IL

Maria Shirey—Shirey & Associates, IN

Jean Slutsky—AHRQ, MD

Kaye Spence—Children’s Hospital at Westmead, Sydney, Australia

Janet Tucker—University of Aberdeen, United Kingdom

Tasnim Vira—University of Toronto, Ontario, Canada

Judith Warren—University of Kansas, KS

Jon White—AHRQ, MD

Zane Robinson Wolf—La Salle University, PA

Laura Zitella—Stanford University Cancer Center, CA