# Contributing Authors

Kathryn Rhodes Alden, M.S.N., R.N., I.B.C.L.C.

University of North Carolina at Chapel Hill

Kristine Alster, Ed.D., R.N.

University of Massachusetts at Boston

Lisa Antle, A.P.R.N., B.C., A.P.N.P

University of Wisconsin Milwaukee College of Nursing

Elizabeth A. Ayello, Ph.D., R.N., A.P.R.N., B.C., C.W.O.C.N., F.A.P.W.C.A., F.A.A.N.

Advances in Skin and Wound Care

Jane H. Barnsteiner, Ph.D., R.N., F.A.A.N.

University of Pennsylvania School of Nursing and Hospital of the University of Pennsylvania

Ann Bemis, M.L.S.

Rutgers, The State University of New Jersey

Patricia Benner, R.N., Ph.D., F.A.A.N.

Carnegie Foundation for the Advancement of Teaching

Mary A. Blegen, Ph.D., R.N., F.A.A.N.

School of Nursing, University of California, San Francisco

Jacqueline F. Byers, Ph.D., R.N., C.N.A.A., C.P.H.Q.

College of Nursing, University of Central Florida, Orlando

Carol H. Cain, Ph.D.

Care Management Institute, Kaiser Permanente

Pascale Carayon, Ph.D.

University of Wisconsin-Madison

Claire C. Caruso, Ph.D., R.N.

National Institute for Occupational Safety and Health

Sean P. Clarke, R.N., Ph.D., C.R.N.P., F.A.A.N.

University of Pennsylvania School of Nursing

Amy S. Collins, B.S., B.S.N., M.P.H.

Centers for Disease Control and Prevention

Karen Cox, R.N., Ph.D., C.N.A.A., F.A.A.N.

Children’s Mercy Hospitals and Clinics, Kansas City, MO

Leanne Currie, D.N.Sc., M.S.N., R.N.

Columbia University School of Nursing

Margaret J. Cushman, Ph.D.(c), R.N., F.H.H.C., F.A.A.N.

University of Massachusetts at Boston

Maureen Ann Dailey, R.N., M.S.

Columbia University School of Nursing

Elizabeth Dayton, M.A.

Johns Hopkins University

Andrea Deickman, M.S.N., R.N.

iTelehealth Inc.

Joanne Disch, Ph.D., R.N., F.A.A.N.

University of Minnesota School of Nursing

Molla Sloane Donaldson, Dr.P.H., M.S.

M.S.D. Healthcare

Nancy E. Donaldson, R.N., D.N.Sc., F.A.A.N.

University of California, San Francisco, School of Nursing

Carol Fowler Durham, M.S.N., R.N.,

University of North Carolina at Chapel Hill

Victoria Elfrink, Ph.D., R.N.B.C.

College of Nursing of Ohio State University and iTelehealth Inc.

Carol Hall Ellenbecker, Ph.D., R.N.

University of Massachusetts at Boston

Marybeth Farquhar, R.N., M.S.N., C.A.G.S.

Agency for Healthcare Research and Quality

Kathy Fletcher, R.N., G.N.P., A.P.R.N.-B.C., F.A.A.N.

University of Virginia Health System

Mary Ann Friesen, M.S.N., R.N., C.P.H.Q.

Center for American Nurses, Silver Spring, MD

Jeanne M. Geiger-Brown, Ph.D., R.N.

University of Maryland School of Nursing

Karen K. Giuliano, R.N., Ph.D., F.A.A.N.

Philips Medical Systems

Barbara Given, Ph.D., R.N., F.A.A.N.

Michigan State University College of Nursing

Ayse P. Gurses

University of Minnesota-Twin Cities

Saira Haque, M.H.S.A., Doctoral candidate

Syracuse University

Kerm Henriksen, Ph.D.

Agency for Healthcare Research and Quality

Ronda G. Hughes, Ph.D., M.H.S., R.N.

Agency for Healthcare Research and Quality

Bonnie M. Jennings, D.N.Sc., R.N., F.A.A.N.

Colonel, U.S. Army (Retired) and health care consultant

Meg Johantgen, Ph.D., R.N.

University of Maryland School of Nursing

Gail M. Keenan, Ph.D., R.N.

University of Illinois, Chicago

Margaret A. Keyes, M.A.

Agency for Healthcare Research and Quality

Ruth M. Kleinpell, Ph.D., R.N., F.A.A.N.

Rush University College of Nursing, Chicago, IL

Susan R. Lacey, R.N., Ph.D.

Nursing Workforce and Systems Analysis, Children’s Mercy Hospitals and Clinics, Kansas City, MO

Jane A. Lipscomb, Ph.D., R.N., F.A.A.N.

University of Maryland School of Nursing

Carol J. Loveland-Cherry, Ph.D., R.N., F.A.A.N.

University of Michigan School of Nursing

Vicki A. Lundmark, Ph.D.

American Nurses Credentialing Center

Courtney H. Lyder, N.D., G.N.P., F.A.A.N.

University of Virginia

Mary Mandeville, M.B.A.

University of Illinois, Chicago

Karen Dorman Marek, Ph.D., M.B.A., R.N., F.A.A.N.

University of Wisconsin Milwaukee College of Nursing

Diana J. Mason, R.N., Ph.D., F.A.A.N.

American Journal of Nursing

Margo McCaffery, R.N., F.A.A.N.

Pain management consultant

Pamela H. Mitchell, Ph.D., R.N., C.N.R.N., F.A.A.N., F.A.H.A.

University of Washington School of Nursing

Deborah F. Mulloy, M.S.N., C.N.O.R., Doctoral student

University of Massachusetts at Boston School of Nursing

Cindy L. Munro, R.N., A.N.P., Ph.D., F.A.A.N.

Virginia Commonwealth University School of Nursing

Mike R. Murphy, R.N., B.S.N., M.B.A.

Synergy Health/St. Joseph’s Hospital

Audrey L. Nelson, Ph.D., R.N., F.A.A.N.

James A. Haley Veterans’ Hospital, Tampa, FL

Michelle O’Daniel, M.H.A., M.S.G.,

VHA West Coast

Eileen T. O’Grady, Ph.D., R.N., N.P.

Nurse Practitioner World News and The American Journal for Nurse Practitioners

Ann E. K. Page, R.N., M.P.H.

Institute of Medicine

Chris Pasero, R.N.

Pain management consultant

Emily S. Patterson, Ph.D.

Cincinnati VA Medical Center and Ohio State University

Nirvana Huhtala Petlick

Rutgers, The State University of New Jersey

Shobha Phansalkar, R.Ph., Ph.D.

Harvard Medical School

Sally Phillips, Ph.D., R.N.

Agency for Healthcare Research and Quality

Gail Powell-Cope, Ph.D., A.R.N.P., F.A.A.N.

James A. Haley Veterans Hospital, Tampa, FL

John Reiling, Ph.D., M.H.A., M.B.A.,

Synergy Health/St. Joseph’s Hospital

Susan C. Reinhard, Ph.D., M.S.N., F.A.A.N.

Rutgers, The State University of New Jersey

Victoria L. Rich, Ph.D., R.N., F.A.A.N.

University of Pennsylvania Health System

Ann E. Rogers, Ph.D., R.N., F.A.A.N.

University of Pennsylvania School of Nursing and University of Pennsylvania School of Medicine

Alan H. Rosenstein, M.D., M.B.A.

VHA West Coast

Linda Samia, Ph.D., R.N.

Healthy Choices for ME, MaineHealth’s Partnership for Healthy Aging

Barbara A. Sattler, R.N., Dr.P.H., F.A.A.N.

University of Maryland School of Nursing

Lucy A. Savitz, Ph.D., M.B.A.

Abt Associates

Loretta Schlachta-Fairchild, R.N., Ph.D., F.A.C.H.E.

iTelehealth Inc.

Jean Ann Seago, Ph.D., R.N.

School of Nursing, University of California, San Francisco

Victoria L. Selby, R.N., B.S.N.

University of Maryland School of Nursing

Laura Senn, M.S., R.N.

University of Minnesota School of Nursing

Janis B. Smith, R.N., M.S.N.

Children’s Mercy Hospitals and Clinics, Kansas City, MO

Elizabeth S. Soule

University of Washington School of Nursing

Nancy Staggers, Ph.D., R.N., F.A.A.N.

University of Utah College of Nursing and School of Medicine

Donald Steinwachs, Ph.D.

Johns Hopkins University

Patricia W. Stone, Ph.D., M.P.H., R.N.

Columbia University School of Nursing

Molly Sutphen, Ph.D.

Carnegie Foundation for the Advancement of Teaching

Marita G. Titler, Ph.D., R.N., F.A.A.N.

University of Iowa Hospitals and Clinics

Alison M. Trinkoff, Sc.D., R.N., F.A.A.N.

University of Maryland School of Nursing

Dana Tschannen, Ph.D., R.N.

University of Michigan.

Mary Wakefield, Ph.D., R.N., F.A.A.N.

University of North Dakota, Grand Forks

Charlene Weir, Ph.D., R.N.

VA Geriatric Research Education and Clinical Centers, Salt Lake City, UT

Nancy Wells, D.N.Sc., R.N., F.A.A.N.

Vanderbilt Medical Center and Vanderbilt University School of Nursing

Susan V. White, Ph.D., R.N., C.P.H.Q., F.N.A.H.Q.

James A. Haley Veterans’ Hospital, Tampa, FL

Zane Robinson Wolf, Ph.D., R.N., F.A.A.N.

La Salle University School of Nursing and Health Sciences

Elizabeth Yakel, Ph.D.

University of Michigan