# 32 Professional Communication

## Background

Instructing nurses on communication is a bit like instructing birds on flying. All nurses have been taught communication skills as a basic part of a prelicensure nursing program and then retaught communication skills in postlicensure programs, continuing education programs, workshops, and meetings. Some nurses would be insulted that anyone would even raise the issue of communication since raising the issue implies that they are deficient in one of the most basic aspects of nursing care. However, the problem with good communication is that it is, ironically, easy to talk about but hard to put into practice. In the literature, there are numerous articles that provide opinion, both expert and otherwise, about communication,1–7 but there is very little evidence about communication practices that have demonstrated an impact upon patient outcomes. The purposes of this chapter are to discuss evidence of professional communication practices or strategies that have been tested empirically and have a relationship with patient outcomes or patient safety, and to provide communication tools that might help practicing nurses maintain and improve patient outcomes and patient safety.

This chapter will focus on communication strategies in hospitals and those related to communication between nurses and physicians. Studies related to communication between physicians and patients or nurses and patients were included if they were determined to be sufficiently methodologically rigorous and had a direct relationship with patient outcomes or patient safety. There is a large body of research on communication in other health care settings and among other professionals, which was not included in this chapter.

### Historical Context

The history of communication between doctors and nurses is well documented. A series of publications begun in 1967 describing the “doctor-nurse game” provides insight into the way nurses have historically made treatment recommendations to doctors without appearing to do so, the way doctors have historically asked nurses for recommendations without appearing to do so, and how both participants strive to avoid open disagreement.8–27 Although some nurses have argued that much has changed—and improved—in the relationships between doctors and nurses since that initial 1967 article, there is little evidence, although much wishful thinking, to support that view.28–31 Additionally, over the years, the literature has contained descriptions of verbal abuse of nurses by physicians,32–35 disruptive physician behavior,36, 37 and advice on how nurses can better “handle” physicians.38–41 So, in spite of much discussion, communication between doctors and nurses often remains contentious and obscure.

### Theoretical Foundations

Many professional groups study communication among humans, and a wide range of theories guides the work. For the purpose of this review, a sample of theories used to describe or study nurse-physician communication will be presented in brief. Habermas’ critical theory has been used to identify successful nurse-physician collaborative strategies, including a willingness to move beyond basic information exchange and to challenge distortions and assumptions in the relationships.42 Theories of Foucault and other poststructuralists that have guided concept analysis of collaboration and explored the notion that the relationship between power and knowledge (knowledge and power are not fixed, meaning not stable, and the idea that there is a hidden or “real” discourse) help explain the relationships between nurses and doctors.43, 44 Various perspectives from the field of organizational behavior, including the structural (behavior is rational) perspective, the human resource (human needs and motivation) perspective, the political (competition for resources) perspective, and the cultural (organizational culture and climate) perspective, have been used to guide activities to improve nurse-physician communication.45

Feminists and scientists have used oppressed-group behavior theory to explain much of nurses’ work and its structure in hospitals, including nurse-physician relationships.34, 46–54 Many scientists and writers have evoked the issue of gender as it relates to the work of nurses and the relationship between nurses and doctors. Early literature related to gender tends to emphasize nurse image, and later work focuses more on nurse job satisfaction; job retention; and differences in decisionmaking, attitudes, perceptions, and ethical or moral dilemmas.55–73 Mark and colleagues argue for theory development related to nurse staffing and patient outcomes, maintaining that one of the important and unexplored areas is the “why” of the nurse-physician relationships and the hypothesis that “enhanced” nurse-physician communication would “result in early recognition and intervention of potentially hazardous patient situations”74 (p. 13).

With the recent emphasis on patient safety, hospital error, and adverse events, some hospital executives have embraced human factors science and training ideas taken from the aviation industry (Crew Resource Management)75 to try to address the issue of patient safety and the lack of collaboration or teamwork in hospital settings. One of the most intriguing recent ideas is the use of the leader-member exchange theory76–88 to describe the interactions between nurses and doctors in hospitals. Hughes and colleagues89, 90 used leader-member exchange theory to create a nurse-physician exchange relationship scale and discussed the relationship between nurses and doctors in terms of a supervisor-employee relationship. The physician can be thought of as being the leader or supervisor of patient care, and the nurse can be thought of as being one of the members or employees providing care. This conceptualization will undoubtedly be challenged by nurses and nurse leaders who advocate for nurse autonomy or nurse independence, but Hughes and colleagues make a compelling argument for viewing the hospital nurse-physician relationship through this theoretical lens. There exists a long and varied history between nurses and doctors, making it difficult to use only one theory to explain all the subtleties of the relationships or to hold the key to improving those relationships.

### Significance—Why Do We Care About Nurse-Physician Communication?

Over the years, there have been repeated cries and admonitions for improving nurse-physician communication and questioning why it is so difficult to achieve.1, 63, 91, 92 Some research has shown that the lack of interpersonal and communication skills of physicians and nurses is associated with errors, inefficiencies in the delivery of care, and frustration.93 There is evidence, though conflicting, that links better collaboration with better patient outcomes, specifically reduced medication errors,45, 94 reduced risk of inpatient mortality,95–98 improved patient satisfaction,99 and some support for efficiency measures such as shorter hospital length of stay.100–103 However, several major reviews and studies found no relationship between nurse-physician collaboration and patient outcomes such as mortality or self-reported health status.100, 102, 103 Physician satisfaction is generally not related to perceived increased collaboration; most frequently the evidence links perceived increased collaboration with nurse satisfaction.4, 36, 104, 105 Additionally, nurses and physicians view the level of collaboration very differently, with nurses typically perceiving less collaboration and poorer communication than physicians.70, 106–108 So, even though the descriptive evidence for improved patient outcomes and improved hospital efficiency is conflicting, it does not clearly negate the premise that better communication and collaboration could have an impact on patient outcomes.

In the nursing literature, nurse-physician communication is discussed or studied using terms such as empowerment, autonomy, collaboration, coordination, teamwork, transitioning, organizational culture, climate, and relationships. Assessment of the descriptive studies listed in the evidence table and references from other studies provide results, information, and opinion about nurse-physician communication, but they are not interventional studies. Some of the more compelling descriptive studies are included in the evidence table but do not meet the rigor required of randomized controlled trials. The setting of much of the descriptive or interventional work is intensive care units, emergency departments, or operating rooms and is often focused on nurse change-of-shift report;109–112 physician/resident handoff/sign-off;113–115 nurse-physician interaction, both routine and emergent;91, 116–118 foreign language use by physicians and nurses;119–124 and communication with patients.125–131

One of the recurring themes in the literature is the difference in perceptions between nurse and physician.36, 69, 70, 106–108, 132–134 Nurses are typically less satisfied than physicians with the communication or interaction patterns and express the need for their opinions to be heard by physicians.133 Areas of particular difference involve those of ethical decision-making and the moral dilemmas confronted by nurses related to these decisions.135–137 There is also a body of literature on the differences between patient and provider (both nurses and physicians) in perceptions of care, quality, or comfort.138–143 Although these papers provide important descriptions and information about nurse, physician, and patient communication, they are only briefly mentioned to provide context for this chapter. The focus of the chapter is on communication between physicians and nurses and whether there is a relationship with patient safety or other patient outcomes.

## Research Evidence

There is no shortage of manuscripts in the literature that advocate, based only on opinion, for one or another method of building teamwork, collaboration, or communication, including recognizing corporate culture,144 quality improvement,145 continuous assessment and regular communication,146 and reducing conflict.147 Other publications detail the experience of one institution or unit in improving communication or teamwork using strategies such as the Comprehensive Unit-Based Safety Program developed at Hopkins,148 Surgical Morning Meetings149 using daily goals in an intensive care unit,150 or interdisciplinary rounds.151 These individual experience descriptions typically report varying outcomes or lack measured outcomes.

### Evidence for Interventions That Improve Positive Communication—What Works?

This review found no randomized controlled trials(RCTs) that investigated communication interventions between nurses and physicians that had a patient outcome as a measure of interest. The RCTs included in the evidence table tested whether various communication training sessions for physicians improved communication with patients.152–157 The evidence indicates that communication training is effective in improving physician attitudes, beliefs, and communication ability. There is also evidence that an intervention called peer leader education155 can result in fewer symptom days, lower oral steroid rates, and reduced cost for children with asthma. In general, longer training programs (2–3 days) had greater positive effects, and the effects were longer lasting. Two RCTs tested the effect of training patients about care using information or technology and found slight improvement in patient perceptions of care.158, 159

Four systematic literature reviews were found that evaluated aspects of communication. One review of 14 studies measured the effect of communication training on physicians, using self-rating of the training effects, but provided no evidence of a relationship between the training and patient compliance or health status, and ambiguous effects on patient psychosocial health.160 The second review of 26 studies concluded that various interventions had no effect on patient expectations, had conflicting lung-function outcomes, improved systolic blood pressure with any interaction, and decreased pain with improved patient-practitioner interaction.161 The third review of 89 studies found no patient outcome changes (health status, disease incidence, cure rates, mortality rates, complication rates) with implementation of interprofessional education versus single-discipline education.162 The fourth review, covering two studies, concluded that after communication training, team development meetings, or weekly rounds, there was no difference in patient mortality rates; but staff satisfaction increased, and there were conflicting results on length of stay.100

The literature search provided three nonrandomized controlled trials (NRCTs) with control groups related to interventions aimed at improving effective communication.163–165 One study described a communication training intervention, a second added personnel (nurse practitioners and hospitalists) and multidisciplinary rounds to the environment, and the third used weekly meetings to discuss role relationships. The first study improved hospital employee work satisfaction and perception of opportunities and decreased information overload.163 The second study improved physician perception of collaboration between nurses and doctors, but produced no change in nurse perception of collaboration.164 The third study decreased consumers’ belief in shared responsibility for care versus a physician-dominated responsibility for care, and increased consumers’ belief that powerful individuals influence a consumer’s health status.165

Included in the evidence tables are seven quality improvement projects without a control or comparison group. These projects are included as examples of the numerous studies in the literature that essentially describe the experience of one or two institutions in implementing an organizational change to improve doctor-nurse collaboration or communication. Dechairo-Marino and colleagues166 report on a teamwork training program that produced no differences in self-reported collaboration or satisfaction; McFerran and colleagues167 describe implementation of a structured communication technique known as Situation-Background-Assessment-Recommendation (SBAR), changing policies, debriefing, and multidisciplinary reports in four Kaiser Permanente sites. No long-term measures are reported, and only the short-term expectations for the “communication initiative” were met. Leonard and colleagues168 report on another Kaiser study of various groups in the organization trained in SBAR, assertion checklists, and briefings. Reported outcomes associated with the intervention include reduced wrong-site surgery, decreased nurse turnover, and improved employee satisfaction; however, no specifics on the measurement of these outcomes are provided. Lassen and colleagues169 describe development and education of a collaborative practice (primarily physician specialists) decisionmaking protocol that was associated with a decrease in rule outsepsis diagnosis, use of antibiotics, patient days, costs, and readmissions in one neonatal intensive care unit (NICU).

Dutton and colleagues170 reported that daily discharge multidisciplinary rounds were related to decreased length of stay in the emergency department and emergency department closures in one trauma center. Copnell and colleagues134 reported no difference in perception of doctor-nurse collaboration after introduction of a nurse practitioner in two NICUs. Boyle4 reported an increase in perceived doctor-nurse communication skills, nurse leadership skills, and problem-solving, and a decrease in nurse stress after a six-module training session called Collaborative Communication Intervention. The designs of these quality projects were too weak to allow any sort of conclusions to be drawn.

## Practice Implications

There is insufficient empirical evidence to recommend any specific communication strategy or technology device to improve doctor-nurse communication. However, there is mixed or weak evidence to support using some of the techniques described in the cited literature. It is likely that focusing an organization on any strategy and persisting in that focus will be associated with, at least temporarily, a change in doctor-nurse communication patterns (e.g., Hawthorne effect). Given the paucity of available evidence, the following suggestions are offered for possible consideration in efforts to improve professional communication:

- Carefully evaluate various strategies for doctor-nurse communication using measurable outcomes that are important to your organization; plan to use a strategy that meets the needs and culture of your organization.
- Select a strategy, focus training, and provide organizational support and sufficient resources toward improving doctor-nurse communication.
- Slowly implement the change using sufficient resources and sufficient time.
- Do not implement multiple changes simultaneously.
- Persist in that strategy for an extended period of time (years, not weeks or months).
- Critically and rigorously evaluate the strategy using patient outcomes and worker satisfaction.
- After allowing sufficient thought and time for implementation and evaluation, be willing to publicly eliminate the strategy if it does not improve the outcomes.

Hospitals have used many communication tools such as written and verbal orders, reports, rounds, and team meetings. As the United States shifted to the “business model” for hospitals, organizations have tried to change culture or climate, create transformational leaders and knowledge workers, implement continuous quality improvement or total quality management, form quality circles, and train the one-minute manager. Some hospitals have used and are currently using technology ranging from pencil and paper, medication rooms and carts, orange vests for the medication nurse so she will have fewer interruptions, Pyxis or other automatic medication dispensers, landline telephones, fax machines, beepers, e-mail, personal digital assistants (PDAs), cellular telephones, wireless devices, direct information transfer, and Web access.

Other recent technology includes mobile communication systems such as Vocera, electronic medical records, computerized physician order entry, and bar-coding for medication administration. A number of organizations are also trying SBAR, organizational support structures such as Rapid Response Teams or techniques such as customer relationship management from business or crew resource management from aviation. Other organizations are trying systems such as Situation-Trajectory-Intent-Concern-Calibrate (STICC) using the Hands-on Automated Nursing Data System Method from the University of Illinois at Chicago and funded by AHRQ, or Gerontology Interdisciplinary Team Training from the Hartford Foundation and the American Geriatrics Society. Few, if any, of these methods or devices have been empirically tested. Without careful consideration and evaluation, efforts to improve communication problems that exist in present-day hospitals may lead to implementation of strategies that will be ineffective.

## Research Implications

Based on the literature review, future research is needed to assess the following:

- What should be the communication competencies of physicians and nurses; and should these competencies be assessed periodically?
- How can health information technologies be used to ensure effective communication between physicians and nurses, across settings and among the various care delivery models?
- What is the impact of effective communication strategies on hospitalized patient outcomes and medical errors?
- What is the impact of effective communication strategies on nurse and physician job satisfaction, and how does provider satisfaction relate to patient outcomes?
- How can communication skills training for practicing physicians and nurses have a career-long impact on their communication skills?

## Conclusion

Within health care, there have been and will continue to be many approaches to professional communication. Unfortunately, the body of evidence is very limited, and the research findings to support professional communication and the relationship with patient safety and quality are not available at this time. There were limited studies that tested specific interventions aimed at changing nurse-physician communication, and there is some evidence that focusing on a doctor-nurse communication may have a positive effect. Health care organizations and providers will be challenged as they seek to improve the effectiveness of professional communication, given all the subtleties of the nurse-physician relationships.

## Search Strategy

Search strategies employed includedthe use of the electroni c databases PubMed®, CINAHL®, the Cochrane Collection, and relevant AHRQ reports. Keywords included physician, nurse, relationships, communication, coordination, collaboration, autonomy, teamwork, MD, RN, patient, outcome, safety, and adverse event. Reference lists of select publications were investigated for potential manuscripts, and literature related to relevant measurement instruments was sought.

Evidence Table

Source | Communication Targets | Design Type | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Randomized Controlled Trials
Ellison 2004^159^ | Patients | Design Type 2 (RCT) (Level 2) questionnaire | Patient satisfaction (Level 3) | 1 hospital 85 patients | Standard care plus1 day telerounding; standard care substituting 1 day with robotic telerounding | Improvement in telerounding patients of examination thoroughness, quality of discussion, postoperative care coordination, availability of MD; in robotic telerounding improvement in availability of MD.
Fallowfield 2003^153^ | MD/patient | Design Type2 (RCT)— pre/postvideotape (Level 2) | At 12 months, same as 3 months (Level 3) | Oncology MDs, UK | 3 day residential communication skills training course | Same effect with use of leading questions, open-ended questions, and response to patient cues; improvement in fewer interruptions, increased summarizing; decline in expressions of empathy.
Jenkins 2002^152^ | MD/pt | Design Type 2 (RCT)—P-P videotape (Level 2) | At 3 months attitudes, empathy, responses (Level 3) | Oncology MDs, UK | 3 day residential communication skills training course | Improved attitudes and beliefs toward psychosocial issues compared to controls; increased expressions of empathy; open questions; appropriate responses to patient cues and psychosocial probing; self-reported changes in communication styles.
Joos 1996^157^ | MD/pt | Design Type 2 (RCT)—P-P questionnaire (Level 2) | Communication skills (Level 3), and compliance and utilization (Level 2) | 42 MDs and 348 patients with chronic conditions | 4.5 hours of training | Increased number of times MDs elicited patient and RN concerns, increased patient perception of amount of information received, no change in patient compliance with medications or appointments; no change in patient utilization.
Levinson 1993^156^ | MD/pt | Design Type2 (RCT)—P-P audiotape (Level 2) | Communication skills (Level 3) | 53 community-based MDs and 473 patients | A short CME program (4.5 hours) and a long CME program (2.5 days) | Short program: no effect. Long program: more open-ended questions, asked patient opinions, gave more biomedical information, patients disclosed more information, decrease in negative affect for both, patients had fewer signs of outward distress during visit.
Lozano 2004^154^ | MD/children (3–17) with asthma | Design Type2 (RCT)—cluster P- P interview and questionnaire (Level 2) | Asthma symptom days, asthma-specific functional status, frequency of oral steroid courses (Level 1) | 42 primary care practices in 3 locations | Peer leader education (PLE) and peer leader + nurse-mediated organizational change (PACI) | Peer leader: fewer symptom days per year & lower oral steroid rates. Peer leader + nurse: fewer symptom days per year & greater adherence to treatment by parent report.
Sullivan 2005^155^ | MD/children (3–17) with asthma | Design Type 2 (RCT)—cluster P- P interview and questionnaire (Level 2) | Symptom-free days (SFDs); asthma-related health care costs (Level 1) | 42 primary care practices in 3 locations | Peer leader education (PLE) and peer leader + nurse-mediated organizational change (PACI) | SFD: 6.5 with PLE vs. usual, 13.5 with PACI vs. usual; compared with usual incremental cost effectiveness ratio was $18/SFD gained for PLE and $68/SFD gained for PACI.
Tran 2002^158^ | ED patients | Design Type 2 (RCT) (Level 2) questionnaire | Patient length of stay (LOS), wait time, perception of LOS, ratings of nurse skills and MD skills (Levels 3 & 4) | 1 hospital ED 619 patients | Providing patients with information q 15 minutes during stay | No difference in LOS, wait time, nurse skills. Decrease in perceived LOS and wait time and increase in perception of MD skills.
Nonrandomized Controlled Trials and Quality Improvement (QI) Projects
Boyle 2004^4^ | MDs/RNs | Design Type 6 P-P 2 units no control (Level 5) | Communication skills, increased staff satisfaction, lower stress, increased problem-solving using videotape vignettes, questionnaire | 1 ICU from 2 hospitals | Collaborative Communication Intervention over 8 months: 23.5 hours for 6 modules | Increased perceived RN and MD communication skills, improved nurse leadership and problem-solving, decreased staff nurse personal stress.
Copnell 2004^134^ | MDs/RNs | Design Type 6 P-P 2 units no control (Level 5) | Perception of collaboration | 2 NICUs | Added NP | No difference before and after NP; MDs and RNs disagreed about collaboration with MDs scoring higher.
Dechairo-Marino 2001^166^ | RNs | Design Type 6 action research— P-P 1 group-no control (Level 5) | RN reports of collaboration with MDs and RN Satisfaction with decisionmaking process- (Level 3) | 1 university teaching hospital; RNs in 3 med-surg units and 2 ICUs | Activities to promote interdisciplinary teamwork between MDs/RNs, including developing principles, discussion in meetings, 1 4- hour class on decisionmaking | No differences
Dutton 2002^170^ | MDs, nurses, patients discharge planners | Design Type 8-no control group (Level 5) | Patient volume, LOS, ED closure (Level 3, 4) | 1 hospital trauma service | Daily discharge multidisciplinary rounds | Increase in patient volume, decrease in LOS, decrease in ED closure.
Lassen 1997^169^ | Well-newborn nurses, pediatricians, neonatologists | Design Type 13- QI project with a control time (Level 5) | # of admissions with R/O sepsis, LOS, # of doses of antibiotics, costs, # of readmissions, reduction in practice variation (Levels 1, 2, 3) | 1 tertiary hospital | Collaborative practice decisionmaking protocol development; education | Decrease in # of R/O sepsis diagnosis, decease in % of patients treated with antibiotics, decrease in patient days, decrease in costs, decrease in readmissions.
Leonard 2004^168^ | Various groups in Kaiser Permanente | Design Type 14- QI project-no control (Level 5) | Improve communication and teamwork by standardized communication (Level 3) | different groups of MDs and RNs | Introduce standardized communication methods such as SBAR, assertion, checklists, critical event training, and briefings | Standardized briefings related to reduced wrong-site surgery, decreased nurse turnover, improved employee satisfaction, improved teamwork climate, communication, and taking responsibility for errors—but few specifics provided.
McFerran 2005^167^ | Perinatal RNs, certified registered nurse anesthesists and MDs | Design Type 13 QI project-no control (Level 5) | Long-term measures: birth event data, medical-legal data, patient satisfaction data (Levels 1 & 2); short-term measures: implementation of 2–3 interventions using human factors technique during 1 year (Level 3) | 4 Kaiser Permanente medical centers perinatal staff | 4-hour human factors education program, SBAR communication technique, revising escalation policy, identifying safe communications, debriefs after adverse events, multidisciplinary reports, assertion, just culture statement (Level 3) | No long-term measures reported; 4 sites met short-term expectations for only communication initiatives.
Roberts 1976^163^ | Hospital employees (non-MD and nonsupervisors) | Design Type 3— NRCT-P-P 2 groups with 1 being control (Level 3) | Employee perception of organizational communication, job satisfaction, and opportunities for innovative job behavior (Level 3) | 1 urban hospital; ED staff members | 2.5–3 hour training sessions weekly for 4 consecutive weeks | Increase satisfaction with work, pay, coworkers, job; increase perception of opportunities for innovation; increase desire for interaction with peers; and decrease in information overload.
Weiss 1985^165^ | MD/RN/consumer | Design Type 3— NRCT with 3 groups, with 2 being matched control groups (Level 3) | Belief regarding value of shared versus physician-dominated responsibility for health care and beliefs that powerful individuals influence consumer health status (Level 4) | Recruited in large urban area | Discussion of role relationships, and problems for 2.5 hours 1 evening/month for 20 months | Decline in belief in shared versus physician-dominated responsibility for health care and increase in belief that powerful individuals influence the consumer’s health status.
Vazirani 2005^164^ | Unit organization; RN, MD, residents, hospitalist, NP | Design Type 3— NCRT 2 groups with 1 being control (Level 3) | Collaboration, communication (Level 3) | 1 hospital; 1 control unit and 1 intervention unit | Added NP, hospitalist, daily multidisciplinary rounds | Perception by MDs of greater collaboration between physicians and nurses with largest effect with residents, between physicians and NPs, better communication between MDs; no difference in nurse perception of communication or collaboration between nurses and MDs, nurses perceived better communication with NPs than MDs.
Systematic Literature Reviews
Di Blasi 1996 (Cochrane Collaboration-Centre for Reviews and Dissemination)161 | Patients with various health problems | Design Type 11 structured review (Level 1) RCTs with and without placebo | Health outcome, symptom resolution, functional status (Level 1); health service use, medication adherence, anxiety, satisfaction (Level 3) | 26 studies with 3,811 participants: poor quality studies with small sample sizes | Various treatments or disease management, including labeling, changing patient expectations, combining treatment information with emotional support | Labeling: no effect; changing patient expectations: conflicting results—improved lung function with suggestion of drug effects but improved systolic blood pressure following any interaction; combined information with support: improved outcomes, mixed result—6 studies found decrease in pain with improved patient-practitioner interaction, style of interaction can influence physical health but with small effects.
Hulsman 1999 (Cochrane Collaboration-Centre for Reviews and Dissemination)160 | Graduate or postgraduate MDs | Design Type 11 structured review (Level 1); evaluation studies RCT and NRCT P-P video, discussion, role play, audio, written, self-rating | Receptive behaviors, information behavior, interpersonal and affective behavior, psychosocial problems and emotions (Level 3); compliance, health status, psychosocial status (Level 2) | 14 studies, 408 participants, 135 controls | Training, education using lecture, modeling, discussion, role play—4–96 hours over 2 days to 6 months | 10 studies report some training effect with best designed reporting fewest effects; improved self-rating of communication and recognition of psychosocial patient problems, no conclusive patient compliance effect, no effect on health status, ambiguous effect of psychosocial health. The other 4 studies report no effects.
Zwarenstein 2000 (The Cochrane Collaboration)100 | Chiropodists/podiatrists, dentists, dietitians, MDs, hygienists, psychologists, nurses, pharmacists, occupational therapists, and others | Design Type 11 structured review (Level 1); RCT, controlled before and after, and interrupted time series | Self-reported health status, disease incidence, cure rates, mortality, complication rates (Level 1); adherence, satisfaction, continuity of care, costs (Level 3) | 89 studies; none met the inclusion criteria | Interprofessional education (IPE) versus single-discipline education | No conclusive evidence of the effectiveness of IPE in relation to professional practice or health outcomes.
Zwarenstein 2000 (The Cochrane Collaboration)100 | MDs/RNs | Design Type 11 structured review (Level 1); RCT, controlled before and after, and interrupted time series | MD/RN collaboration/joint decisionmaking (Level 3), costs(Level 4); LOS, mortality (Level 1) | 2 studies with 1,102 admissions in one and 417 admissions in the other | Training, workshops, ward reorganization, team development, meetings, patient-centered care, 4 times weekly rounds, weekly case conference | 1st study: shorter LOS, reduced costs, no difference in mortality rate, increased staff satisfaction. 2nd study: no difference in LOS and no difference in mortality rates.
Descriptive
Aiken 1994^171^ | MDs/RNs | Design Type 4 cross-sectional (Level 5) | Medicare mortality rates (Level 1) | 39 Magnet hospitals, 139 controls | None | Magnet hospitals (higher autonomy, control, MD relationships, RN hours, skill mix) had lower Medicare mortality rates.
Aiken 1999^99^ | MDs/RNs | Design Type 4 cross-sectional (Level 5) | 30-day mortality, patient satisfaction, nurse-patient ratios, control by bedside nurses; specialty physicians (Levels 1, 3) | 40 units in 20 hospitals; 1,205 patients and 820 nurses | None | Better nurse-patient ratios, lower mortality; higher nurse control, higher patient satisfaction.
Alt-White 1983^105^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Nurse-physician collaboration (Level 3) | 46 units, 446 nurses | None | Primary nurse, critical care units, unit communication, coordination, nurse satisfaction associated with better collaboration.
Baggs 1997^107^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Nurse/physician collaboration and satisfaction with decisionmaking, nurse retention (Level 3) | 3 ICUs in 3 hospital | None | Collaboration was associated with satisfaction for all but more strongly for nurses; nurse satisfaction with decisionmaking was not associated with retention.
Baggs 1999^95^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Mortality, ICU readmission (Level 1) | 3 ICUs in 3 hospitals | None | In the medical ICU, there was an association between nurse perception of collaboration and lower risk of patient death or ICU readmission; MD reports of collaboration were not associated with patient outcomes.
Estabrooks 2005^98^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5 | 30-day mortality | 49 hospitals | None | Greater nurse-physician relationships, more temporary positions, higher nurse education level, and richer skill mix associated with better 30-day mortality.
Kaissi 2003^106^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Nurse-physician interpersonal interaction/teamwork (Level 3) | 2 hospitals | None | 78% of nurses rated experience with MDs as very low/low or adequate.
King 1994^108^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Nurse-physician collaboration (Level 3) | 90 nurses, 40 physicians, 4 hospitals, and 2 hospital ships | None | MDs & RNs disagreed with MDs perceiving higher collaboration than RNs.
Knaus 1986^97^ | MDs/RNs | Design Type 4, 8 cross-sectional with no comparison group (Level 5) | Actual and predicted mortality, coordination of care (Levels 1, 3) | 13 hospitals | None | Hospitals with less actual mortality than predicted had better coordination of care and communication between RNs/MDs and among MDs.
Rosenstein 2002^36^ | RNs/MDs/executives | Design Type 4, 8 cross-sectional with no comparison group (Level 5) | Nurse-physician relationship (Level 3) | Network of hospitals; 1,200 responses from RNs, MDs, executives | None | MDs and RNs were significantly different; more RNs have witnessed disruptive MD behavior, more RNs say the disruptive behavior is important in nurse morale; nurses perceive less support for conflict; nurses perceive MDs as unaware of relationship.
Zimmerman 1993^103^ | MDs/RNs | Design Type 4, 8 cross-sectional with no comparison group (Level 5) | Strong medical and nursing leadership, collaboration, coordination, communication, mortality, LOS (Levels 1, 3) | 9 ICUs in 9 hospitals; 316 RNs and 202 MDs | None | No difference in risk-adjusted mortality or LOS between high-performing and low-performing ICUs.
Shortell 1994^101^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | LOS, nurse turnover, technical quality of care, meeting family needs (Levels 3, 4) | 42 ICUs | None | Higher scores on leadership, coordination, communication, conflict management, associated with shorter LOS, higher technical quality of care, greater ability to meet family needs.
Thomas 2003^70^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | Collaboration, communication (Level 3) | 8 ICUs in 2 hospitals; 90 MDs, 230 RNs | None | Most MDs rated collaboration and communication as high or very high; most RNs rated it as low or very low.
Zimmerman 1991^102^ | MDs/RNs | Design Type 4, 8 cross-sectional no comparison group (Level 5) | ICU LOS, predicted hospital mortality (Levels 1, 3) | 40 hospitals | None | Lower mortality associated with better technological adequacy and work environment; shorter LOS associated with better communication, culture, coordination, conflict management.

## References

1 Grubb LL. (1979). Nurse-physician collaboration. Superv Nurse.
2 Evans JA. (1994). The role of the nurse manager in creating an environment for collaborative practice. Holist Nurs Pract.
3 Taylor-Seehafer M. (1998). Nurse-physician collaboration. J Am Acad Nurse Pract.
4 Boyle DK, Kochinda C. (2004). Enhancing collaborative communication of nurse and physician leadership in two intensive care units. J Nurs Adm.
5 Kalisch BJ, Kalisch PA. (1981). Communicating clinical nursing issues through the newspaper. Nurs Res.
6 Brandi CL. (2000). Relationships between nurse executives and physicians: the gender paradox in healthcare. J Nurs Adm.
7 Smith AP. (2004). Partners at the bedside: the importance of nurse-physician relationships. Nurs Econ.
8 Stein LI. (1967). The doctor-nurse game. Arch Gen Psychiatry.
9 Stein LI. (1968). The doctor-nurse game. Am J Nurs.
10 Thomstad B, Cunningham N, Kaplan BH. (1975). Changing the rules of the doctor-nurse game. Nurs Outlook.
11 Goodwin L, Taylor N. (1977). Doing away with the ‘doctor-nurse game. ’ Superv Nurse.
12 (1978). Nurses respond to doctor-nurse game. Aorn J.
13 Murray FJ. (1986). The maneuvering continues in the doctor-nurse game. Med World News.
14 (1990). Ethics of the ‘doctor-nurse’ game. Heart Lung.
15 (1990). The doctor-nurse game revisited. N Engl J Med.
16 Marsden C. (1990). Ethics of the ‘doctor-nurse game’. Heart Lung.
17 Stein LI, Watts DT, Howell T. (1990). The doctor-nurse game revisited [see comments]. N Engl J Med.
18 Stein LI. (1990). The doctor-nurse game. NLN Publications.
19 Burshuliak D. (1991). Ethics of the doctor-nurse game. Heart Lung.
20 Dayton N. (1992). The old “doctor-nurse game”—today's professional nurses decide to quit playing. Tenn Nurse.
21 Pillitteri A, Ackerman M. (1993). The doctor-nurse game: a comparison of 100 years—1888–1990. Nurs Outlook.
22 Sweet SJ, Norman IJ. (1995). The nurse-doctor relationship: a selective literature review. J Adv Nurs.
23 High L. (1996). Doctor-nurse game. Nurs Outlook.
24 Willis E, Parish K. (1997). Managing the doctor-nurse game: a nursing and social science analysis. Contemp Nurse.
25 Snelgrove S, Hughes D. (2000). Interprofessional relations between doctors and nurses: perspectives from South Wales. J Adv Nurs.
26 Gjerberg E, Kjolsrod L. (2001). The doctor-nurse relationship: how easy is it to be a female doctor cooperating with a female nurse?. Soc Sci Med.
27 Mason DJ. (2002). MD-RN: a tired old dance. Am J Nurs.
28 Mauksch IG. (1981). Nurse-physician collaboration: a changing relationship. J Nurs Adm.
29 Coeling H, Wilcox J. (1991). Professional recognition and high-quality patient care through collaboration: Two sides of the same coin. Focus Critic Care-AACN.
30 Evans SA, Carlson R. (1992). Nurse/physician collaboration: solving the nursing shortage crisis. Am J Crit Care.
31 Teres D. (1994). A different interpretation of management scores. Am J Crit Care.
32 Farrell GA. (1997). Aggression in clinical settings: nurses' views. J Adv Nurs.
33 Seago JA. (1993). Verbal abuse of nurses. Revolution: The Journal of Nurse Empowerment.
34 Cox H. (1991). Verbal abuse nationwide, Part I: Oppressed group behavior. Nurs Manage.
35 Rowe MM, Sherlock H. (2005). Stress and verbal abuse in nursing: do burned out nurses eat their young?. J Nurs Manag.
36 Rosenstein AH. (2002). Original research: nurse-physician relationships: impact on nurse satisfaction and retention. Am J Nurs.
37 Rosenstein AH, O'Daniel M. (2005). Disruptive behavior and clinical outcomes: perceptions of nurses and physicians. Am J Nurs.
38 Friedman FB. (1990). ‘The 'joy' of telling a physician he's wrong.’. NLN Publ.
39 Friedman FB. (1982). A nurse's guide to the care and handling of MDs. RN.
40 Friedman FB. (1982). The 'joy' of telling a physician he's wrong. RN.
41 Davidhizar R, Policinski H, Bowen M. (1990). The difficult doctor. Today's OR nurse.
42 McLain BR. (1988). Collaborative practice: the nurse practitioner's role in its success or failure. Nurse Pract.
43 Henneman EA. (1995). Nurse-physician collaboration: a poststructuralist view. J Adv Nurs J.
44 Henneman EA, Lee JL, Cohen JI. (1995). Collaboration: a concept analysis. J Adv Nurs.
45 Arford PH. (2005). Nurse-physician communication: an organizational accountability. Nurs Econ.
46 Roberts SJ. (1997). Nurse executives in the 1990s: empowered or oppressed?. Nurs Adm Q.
47 Roberts SJ. (1983). Oppressed group behavior: implications for nursing. ANS Adv Nurs Sci.
48 Hedin BA. (1986). A case study of oppressed group behavior in nurses. Image J Nurs Sch.
49 Hedin BA. (1987). Nursing education and social constraints: an in depth analysis. Int J Nurs Stud.
50 Skillings LN. (1992). Perceptions and feelings of nurses about horizontal violence as an expression of oppressed group behavior. NLN Publ.
51 Roberts SJ. (1994). Oppressed group behavior: implications for nursing. Revolution.
52 Priede-Kalnins Z. (1995). Oppression's influence on behavior: first hand impressions. J Cult Divers.
53 Roberts SJ. (1996). Breaking the cycle of oppression: lessons for nurse practitioners?. J Am Acad Nurse Pract.
54 Krejci JW, Malin S. (1997). Impact of leadership development on competencies. Nurs Econ.
55 Lieb R. (1978). Power, powerlessness and potential—nurse's role within the health care delivery system. Image (IN).
56 Bush MA, Kjervik DK. (1979). The nurse's self-image. Nurs Times.
57 Vance CN. (1979). Women leaders: modern day heroines or societal deviants?. Image (IN).
58 Hughes L. (1980). The public image of the nurse. ANS Adv Nurs Sci.
59 Kalisch BJ, Kalisch PA, McHugh ML. (1982). The nurse as a sex object in motion pictures, 1930 to 1980. Res Nurs Health.
60 Grosser LR. (1981). Let's take the bedpan out of the public's image of nursing. Aorn J.
61 Austin JK, Champion VL, Tzeng OC. (1985). Crosscultural comparison on nursing image. Int J Nurs Stud.
62 Joseph DH. (1985). Sex-role stereotype, self-concept, education and experience: do they influence decision-making?. Int J Nurs Stud.
63 Bacon LL. (1986). The nurse-physician relationship: conflict to collaboration. Nebr Nurse.
64 Gray DE. (1989). Militancy, unionism, and gender ideology: a study of hospital nurses. Work & Occupations: an International Sociological Journal.
65 Norwood SL. (2001). The invisibility of advanced practice nurses in popular magazines. J Am Acad Nurse Pract.
66 Dahl M. (1992). Nurses: an image change still needed. Int Nurs Rev.
67 Barkley TW, Kohler PA. (1992). Is nursing's image a deterrent to recruiting men into the profession? Male high school students respond. Nurs Forum.
68 Papathanassoglou ED, Tseroni M, Karydaki A, et al. (2005). Practice and clinical decision-making autonomy among Hellenic critical care nurses. J Nurs Manag.
69 Oberle K, Hughes D. (2001). Doctors' and nurses' perceptions of ethical problems in end-of-life decisions. J Adv Nurs.
70 Thomas EJ, Sexton JB, Helmreich RL. (2003). Discrepant attitudes about teamwork among critical care nurses and physicians. Crit Care Med.
71 Muldoon OT, Kremer JM. (1995). Career aspirations, job satisfaction and gender identity in female student nurses. J Adv Nurs.
72 Aber CS, Hawkins JW. (1992). Portrayal of nurses in advertisements in medical and nursing journals. Image J Nurs Sch.
73 Kaler SR, Levy DA, Schall M. (1989). Stereotypes of professional roles. Image J Nurs Sch.
74 Mark BA, Hughes LC, Jones CB. (2004). The role of theory in improving patient safety and quality health care. Nurs Outlook.
75 Surgenor SD, Blike GT, Corwin HL. (2003). Teamwork and collaboration in critical care: lessons from the cockpit. Crit Care Med.
76 Lamude KG, Scudder J, Simmons D. (2000). Perceptions of leader-member exchange: comparison of permanent and temporary employees. Psychol Rep.
77 Liden RC, Wayne SJ, Sparrowe RT. (2000). An examination of the mediating role of psychological empowerment on the relations between the job, interpersonal relationships, and work outcomes. J Appl Psychol.
78 Schriesheim CA, Castro SL, Yammarino FJ. (2000). Investigating contingencies: an examination of the impact of span of supervision and upward controllingness on leader-member exchange using traditional and multivariate within- and between-entities analysis. J Appl Psychol.
79 Townsend J, Phillips JS, Elkins TJ. (2000). Employee retaliation: the neglected consequence of poor leader-member exchange relations. J Occup Health Psychol.
80 Maslyn JM, Uhl-Bien M. (2001). Leader-member exchange and its dimensions: effects of self-effort and other's effort on relationship quality. J Appl Psychol.
81 Sherony KM, Green SG. (2002). Coworker exchange: relationships between coworkers, leader-member exchange, and work attitudes. J Appl Psychol.
82 van Breukelen W, Konst D, van der Vlist R. (2002). Effects of LMX and differential treatment on work unit commitment. Psychol Rep.
83 Wayne SJ, Shore LM, Bommer WH, et al. (2002). The role of fair treatment and rewards in perceptions of organizational support and leader-member exchange. J Appl Psychol.
84 Hofmann DA, Morgeson FP, Gerras SJ. (2003). Climate as a moderator of the relationship between leader-member exchange and content specific citizenship: safety climate as an exemplar. J Appl Psychol.
85 Kacmar KM, Witt LA, Zivnuska S, et al. (2003). The interactive effect of leader-member exchange and communication frequency on performance ratings. J Appl Psychol.
86 van Breukelen W, Konst D, van der Vlist R. (2004). Reaction to ‘Comments on 'The effects of leader-member exchange and differential treatment on work unit commitment': distinguishing between neutralizing and moderating effects’. Psychol Rep.
87 Xu Y, Barbuto JE. (2004). Comments on “The effects of leader-member exchange and differential treatment on work unit”: distinguishing between neutralizing and moderating effects. Psychol Rep.
88 Chiaburu DS. (2005). The effects of instrumentality on the relationship between goal orientation and leader-member exchange. J Soc Psychol.
89 Hughes L. (2005). Psychometric properties of the nurse-physician exchange relationship scale.
90 Hughes L, Mark B, Russell S, et al. (2005). Deference to nursing expertise in acute care hospitals.
91 Miller PA. (2001). Nurse-physician collaboration in an intensive care unit. Am J Crit Care.
92 Kappeli S. (1995). Interprofessional cooperation: why is partnership so difficult?. Patient Educ Couns.
93 Helmreich RL, Schaefer H. Team performance in the operating room. Bogner MS, editor. Human errors in medicine.
94 Croskerry P, Shapiro M, Campbell S, et al. (2004). Profiles in patient safety: medication errors in the emergency department. Acad Emerg Med.
95 Baggs JG, Schmitt MH, Mushlin AI, et al. (1999). Association between nurse-physician collaboration and patient outcomes in three intensive care units [see comments]. Crit Care Med.
96 Aiken L. (1994). Good nursing care = lower death rates [interview]. N J Nurse.
97 Knaus WA, Draper EA, Wagner DP, et al. (1986). An evaluation of outcome from intensive care in major medical centers. Ann Intern Med.
98 Estabrooks CA, Midodzi WK, Cummings GG, et al. (2005). The impact of hospital nursing characteristics on 30-day mortality. Nurs Res.
99 Aiken LH, Sloane DM, Lake ET, et al. (1999). Organization and outcomes of inpatient AIDS care. Med Care.
100 Zwarenstein M, Bryant W. (2000). Interventions to promote collaboration between nurses and doctors. Cochrane Database Syst Rev.
101 Shortell SM, Zimmerman JE, Rousseau DM, et al. (1994). The performance of intensive care units: does good management make a difference?. Med Care.
102 Zimmerman JE, Knaus WA, Draper EA, et al. (1991). Organizational correlates with ICU efficiency and effectiveness. Crit Care Med.
103 Zimmerman JE, Shortell SM, Rousseau DM, et al. (1993). Improving intensive care: observations based on organizational case studies in nine intensive care units: a prospective, multicenter study [see comments]. Crit Care Med.
104 Van Ess Coeling H, Cukr PL. (2000). Communication styles that promote perceptions of collaboration, quality, and nurse satisfaction. J Nurs Care Qual.
105 Alt-White AC, Charns M, Strayer R. (1983). Personal, organizational and managerial factors related to nurse—physician collaboration. Nurs Adm Q.
106 Kaissi A, Johnson T, Kirschbaum MS. (2003). Measuring teamwork and patient safety attitudes of high-risk areas. Nurs Econ.
107 Baggs JG, Schmitt MH, Mushlin AI, et al. (1997). Nurse-physician collaboration and satisfaction with the decision-making process in three critical care units. Am J Crit Care.
108 King L, Lee JL. (1994). Perceptions of collaborative practice between Navy nurses and physicians in the ICU setting. Am J Crit Care.
109 Wolf ZR. (1989). Learning the professional jargon of nursing during change of shift report. Holist Nurs Pract.
110 Lange LL. (1992). Information seeking by nurses during beginning-of-shift activities. Proc Annu Symp Comput Appl Med Care.
111 Bosek MS, Fugate K. (1994). Intershift report: a quality improvement project. Medsurg Nursing.
112 Yurkovich E, Smyer T. (1998). Shift report: a time for learning. J Nurs Educ.
113 Van Eaton EG, Horvath KD, Lober WB, et al. (2004). Organizing the transfer of patient care information: the development of a computerized resident sign-out system. Surgery.
114 Frank G, Lawless ST, Steinberg TH. (2005). Improving physician communication through an automated, integrated sign-out system. J Healthc Inf Manag.
115 Van Eaton EG, Horvath KD, Lober WB, et al. (2005). A randomized, controlled trial evaluating the impact of a computerized rounding and sign-out system on continuity of care and resident work hours. J Am Coll Surg.
116 Manias E, Street A. (2001). Nurse-doctor interactions during critical care ward rounds. J Clin Nurs.
117 Cook RL. (1979). Physician-nurse collaboration: a nurse's perspective. Aviat Space Environ Med.
118 Watts RJ, Chmielewski C, Holland MT, et al. (1995). Nurse-physician collaboration and decision outcomes in transplant ambulatory care settings. ANNA Journal.
119 O'Neill TR, Marks C, Wendt A. (2005). Recommending a minimum English proficiency standard for entry-level nursing. JONAS Healthc Law Ethics Regul.
120 Abriam-Yago K, Yoder M, Kataoka-Yahiro M. (1999). The Cummins model: a framework for teaching nursing students for whom English is a second language. J Transcult Nurs.
121 Hall P, Keely E, Dojeiji S, et al. (2004). Communication skills, cultural challenges and individual support: challenges of international medical graduates in a Canadian healthcare environment. Med Teach.
122 van Zanten M, Boulet JR, McKinley D, et al. (2003). Evaluating the spoken English proficiency of international medical graduates: detecting threats to the validity of standardised patient ratings. Med Educ.
123 Boulet JR, van Zanten M, McKinley DW, et al. (2001). Evaluating the spoken English proficiency of graduates of foreign medical schools. Med Educ.
124 Rothman AI, Cusimano M. (2001). Assessment of English proficiency in international medical graduates by physician examiners and standardized patients. Med Educ.
125 Cooper-Patrick L, Gallo JJ, Gonzales JJ, et al. (1999). Race, gender, and partnership in the patient-physician relationship. JAMA.
126 Johnson RL, Roter D, Powe NR, et al. (2004). Patient race/ethnicity and quality of patient-physician communication during medical visits. Am J Public Health.
127 Pasco AC, Morse JM, Olson JK. (2004). The cross-cultural relationships between nurses and Filipino Canadian patients. J Nurs Scholarsh.
128 Hill K. (2003). The sound of silence—nurses' non-verbal interaction within the ward round. Nurs Crit Care.
129 McKnight L, Stetson PD, Bakken S, et al. (2001). Perceived information needs and communication difficulties of inpatient physicians and nurses. Proc AMIA Symp.
130 Goodman GR. (2004). How can nurses help patients work more effectively with nurses to improve the safety of patient care?. Nurs Econ.
131 Mallett J. (1990). Communication between nurses and post-anaesthetic patients. Intensive Care Nurs.
132 Baggs JG, Schmitt MH. (1997). Nurses' and resident physicians' perceptions of the process of collaboration in an MICU. Res Nurs Health.
133 Larson E, Hamilton HE, Mitchell K, et al. (1998). Hospitalk: an exploratory study to assess what is said and what is heard between physicians and nurses. Clin Perform Qual Health Care.
134 Copnell B, Johnston L, Harrison D, et al. (2004). Doctors' and nurses' perceptions of interdisciplinary collaboration in the NICU, and the impact of a neonatal nurse practitioner model of practice. J Clin Nurs.
135 Grundstein-Amado R. (1992). Differences in ethnical decision-making processes among nurses and doctors. J Adv Nurs.
136 Wilkinson JM. (1987/1988). Moral distress in nursing practice: experience and effect. Nurs Forum.
137 Pike AW. (1991). Moral outrage and moral discourse in nurse-physician collaboration. J Prof Nurs.
138 Patistea E, Vardaki Z. (2001). Clients' and nurses' perspectives on caring as related to nursing leadership—the Hellenic dimension. Part One. Can J Nurs Leadersh.
139 Hartmuller VW, Desmond SM. (2004). Professional and patient perspectives on nutritional needs of patients with cancer. Oncol Nurs Forum.
140 Biancofiore G, Bindi ML, Romanelli AM, et al. (2005). Stress-inducing factors in ICUs: what liver transplant recipients experience and what caregivers perceive. Liver Transpl.
141 Florin J, Ehrenberg A, Ehnfors M. (2005). Patients' and nurses' perceptions of nursing problems in an acute care setting. J Adv Nurs.
142 Mair FS, Goldstein P, May C, et al. (2005). Patient and provider perspectives on home telecare: preliminary results from a randomized controlled trial. J Telemed Telecare.
143 Young WB, Minnick AF, Marcantonio R. (1996). How wide is the gap in defining quality care? Comparison of patient and nurse perceptions of important aspects of patient care. J Nurs Adm.
144 Spicer J. (1991). Building teamwork by recognizing corporate cultures in the hospital. Trustee.
145 Eubanks P. (1991). Quality improvement key to changing nurse-MD relations. Hospitals.
146 Blair PD. (2003). Continuous assessment and regular communication foster patient safety. Nurs Manage.
147 Iacono M. (2003). Conflict, communication, and collaboration: Improving interactions between nurses and physicians. J Perianesth Nurs.
148 Ball M. (2005). Culture of safety. Advances for Nurses.
149 Aston J, Shi E, Bullot H, et al. (2005). Qualitative evaluation of regular morning meetings aimed at improving interdisciplinary communication and patient outcomes. Int J Nurs Pract.
150 Pronovost P, Berenholtz S, Dorman T, et al. (2003). Improving communication in the ICU using daily goals. J Crit Care.
151 Halm MA, Gagner S, Goering M, et al. (2003). Interdisciplinary rounds: impact on patients, families, and staff. Clin Nurse Spec.
152 Jenkins V, Fallowfield L. (2002). Can communication skills training alter physicians' beliefs and behavior in clinics?. J Clin Oncol.
153 Fallowfield L, Jenkins V, Farewell V, et al. (2003). Enduring impact of communication skills training: Results of a 12-month follow-up. Br J Cancer.
154 Lozano P, Finkelstein JA, Carey VJ, et al. (2004). A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med.
155 Sullivan SD, Lee TA, Blough DK, et al. (2005). A multisite randomized trial of the effects of physician education and organizational change in chronic asthma care: cost-effectiveness analysis of the Pediatric Asthma Care Patient Outcomes Research Team II (PAC-PORT II). Arch Pediatr Adolesc Med.
156 Levinson W, Roter D. (1993). The effects of two continuing medical education programs on communication skills of practicing primary care physicians. J Gen Intern Med.
157 Joos SK, Hickam DH, Gordon GH, et al. (1996). Effects of a physician communication intervention on patient care outcomes. J Gen Intern Med.
158 Tran TP, Schutte WP, Muelleman RL, et al. (2002). Provision of clinically based information improves patients' perceived length of stay and satisfaction with EP. Am J Emerg Med.
159 Ellison L, Pinto P, Kim F, et al. (2004). Telerounding and patient satisfaction after surgery. J Am Coll Surg.
160 Hulsman RL, Ros WJ, Winnubst JA, et al. (1999). Teaching clinically experienced physicians communication skills: a review of evaluation studies. Med Educ.
161 Di Blasi Z, Harkness E, Ernst E, et al. (1996). Health and patient practitioner interactions: a systematic review.
162 Zwarenstein M, Reeves S, Barr H, et al. (2001). Interprofessional education: effects on professional practice and health care outcomes. Cochrane Database Syst Rev.
163 Roberts K, Cerruti N, O'Reilly C. (1976). Changing perceptions of organizational communication: can short-term intervention help?. Nurs Res.
164 Vazirani S, Hays RD, Shapiro MF, et al. (2005). Effect of a multidisciplinary intervention on communication and collaboration among physicians and nurses. Am J Crit Care.
165 Weiss SJ. (1985). The influence of discourse on collaboration among nurses, physicians, and consumers. Res Nurs Health.
166 Dechairo-Marino AE, Jordan-Marsh M, Traiger G, et al. (2001). Nurse/physician collaboration: action research and the lessons learned. J Nurs Adm.
167 McFerran S, Nunes J, Pucci D, et al. (2005). Perinatal Patient Safety Project: a multicenter approach to improve performance reliability at Kaiser Permanente. J Perinat Neonatal Nurs.
168 Leonard M, Graham S, Bonacum D. (2004). The human factor: the critical importance of effective teamwork and communication in providing safe care. Qual Saf Health Care.
169 Lassen AA, Fosbinder DM, Minton S, et al. (1997). Nurse/physician collaborative practice: improving health care quality while decreasing cost. Nurs Econ.
170 Dutton R, Coooper C, Jones A, et al. (2002). Daily multidisciplinary rounds shorten length of stay for trauma patients. J Trauma.
171 Aiken LH, Smith HL, Lake ET. (1994). Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care.
172 Shortell SM, Rousseau DM, Gillies RR, et al. (1991). Organizational assessment in intensive care units (ICUs): construct development, reliability, and validity of the ICU nurse-physician questionnaire. Med Care.
173 Roberts K, O'Reillly C. (1974). Measuring organizational communication. J Appl Psychol.
174 Choi J, Bakken S, Larson E, et al. (2004). Perceived nursing work environment of critical care nurses. Nurs Res.
175 Weiss SJ, Davis HP. (1985). Validity and reliability of the Collaborative Practice Scales. Nurs Res.
176 Aiken LH, Patrician PA. (2000). Measuring organizational traits of hospitals: the Revised Nursing Work Index. Nurs Res.
177 Temkin-Greener H, Gross D, Kunitz S, et al. (2004). Measuring interdisciplinary team performance in a long-term care setting. Med Care.
178 Baggs JG. (1994). Development of an instrument to measure collaboration and satisfaction about care decisions. J Adv Nurs.
179 Dougherty MB, Larson E. (2005). A review of instruments measuring nurse-physician collaboration. J Nurs Adm.

## Appendix

Measurement Instruments

Source | Measurement Instrument | Concepts | Number of Items & Response Style
Shortell 1991^172^ | ICU Nurse-Physician Questionnaire; 48 items selected from the Organizational Culture Inventory (OCI) | Organizational culture, leadership, communication, coordination, problem-solving | 48 items; 1–5 point Likert scale
Roberts 1974^173^ | Organizational Communication | Communication | 35 items; 7–10 point Likert scale
Choi 2004^174^ | Perceived Nursing Work Environment (PNWE) | Nursing management, nursing process, RN/MD collaboration, nursing competence, scheduling climate | 42 items; 4 point Likert scale
Weiss 1985^175^ | Collaborative Practice Scales | RN/MD interaction and influence on patient care | 9 items RN & 10 items MD; 6 point Likert scale
Aiken 2000^176^ | Nursing Work Index-Revised (NWI-R) | Autonomy, RN/MD relationships, control of practice | 57 items; 4 point Likert scale
Temkin-Greener 2004^177^ | PACE team performance questionnaire | Interdisciplinary team performance | 59 items; 5 point Likert scale
Baggs 1994^178^ | Collaboration and Satisfaction About Care Decisions (CSACD) | RN/MD collaboration | 14 items; 7 point Likert scale
Dougherty 2005^179^ | A review of instruments measuring RN/MD collaboration | RN/MD collaboration | Collaborative Practice Scale, Collaboration and Satisfaction About Care Decisions, ICU Nurse-Physician Questionnaire, Nurses Opinion Questionnaire, and the Jefferson Scale of Attitudes Toward Physician-Nurse Collaboration