# 10 Fall and Injury Prevention

## Background

Fall and injury prevention continues to be a considerable challenge across the care continuum. In the United States, unintentional falls are the most common cause of nonfatal injuries for people older than 65 years. Up to 32 percent of community-dwelling individuals over the age of 65 fall each year, and females fall more frequently than males in this age group.1, 2 Fall-related injuries are the most common cause of accidental death in those over the age of 65, resulting in approximately 41 fall-related deaths per 100,000 people per year. In general, injury and mortality rates rise dramatically for both males and females across the races after the age of 85, but males older than 85 are more likely to die from a fall than females.2–6 Unfortunately, fall-related death rates in the United States increased between 1999 and 2004, from 29 to 41 per 100,000 population.2, 7 Sadly, these rates are moving away from the Healthy People 2010 fall-prevention goal, which specifically seeks to reduce the number of deaths resulting from falls among those age 65 or older from the 2003 baseline of 38 per 100,000 population to no more than 34 per 100,000.^8^ Thus, falls are a growing public health problem that needs to be addressed.

The sequelae from falls are costly. Fall-related injuries account for up to 15 percent of rehospitalizations in the first month after discharge from hospital.9 Based on data from 2000, total annual estimated costs were between $16 billion and $19 billion for nonfatal, fall-related injuries and approximately $170 million dollars for fall-related deaths across care settings in the community.10, 11 Several factors have been implicated as causes of falls and injuries; to date, however, no definitive predictor profile has been identified. Although the underlying status of the individual who sustains a fall may contribute to the fall and subsequent injury, the trauma resulting from the fall itself is most often the cause of morbidity and mortality.

Over the past 20 years gerontology researchers, spearheaded by Mary Tinnetti from Yale University, have carried out a significant amount of research to address the problem of falls and injuries in the community. However, ubiquitous use of successful interventions is not yet in place in the community. As health care moves toward patient-centered care, and as a growing body of research provides guidance for widespread fall-prevention programs, fall- and fall-related-injury prevention now has the potential to be addressed across the care continuum.

Inpatient fall prevention has been an individual area of concern for nursing for almost 50 years.12, 13 Traditional hospital-based incident reports deem all inpatient falls to be avoidable, and therefore falls are classified as adverse events. Indeed, falls are the most frequently reported adverse events in the adult inpatient setting. But underreporting of fall events is possible, so injury reporting is likely a more consistent quality measure over time and organizations should consider judging the effects of interventions based on injury rates, not only fall rates. Inpatient fall rates range from 1.7 to 25 falls per 1,000 patient days, depending on the care area, with geropsychiatric patients having the highest risk.14–18 Extrapolated hospital fall statistics indicate that the overall risk of a patient falling in the acute care setting is approximately 1.9 to 3 percent of all hospitalizations.16–18 In the United States, there are approximately 37 million hospitalizations each year;19 therefore, the resultant number of falls in hospitals could reach more than 1 million per year.

Injuries are reported to occur in approximately 6 to 44 percent of acute inpatient falls.5, 20–23 Serious injuries from falls, such as head injuries or fractures, occur less frequently, 2 to 8 percent, but result in approximately 90,000 serious injuries across the United States each year.20 Fall-related deaths in the inpatient environment are a relatively rare occurrence. Although less than 1 percent of inpatient falls result in death, this translates to approximately 11,000 fatal falls in the hospital environment per year nationwide. Since falls are considered preventable, fatal fall-related injuries should never occur while a patient is under hospital care.

In the long-term care setting, 29 percent to 55 percent of residents are reported to fall during their stay.24, 25 In this group, injury rates are reported to be up to 20 percent, twice that of community-dwelling elderly. The increase in injury rates is likely because long-term care residents are more vulnerable than those who can function in the community.26 Rubenstein27 reported 1,800 long-term care fatal falls in the United States during1988. The current number of long-term care fatal falls has not been estimated; however, there are 16,000 nursing homes in the United States caring for 1.5 million residents in 2004.^28^ This population will likely grow in the coming years, thus fall and injury prevention remains of utmost concern.

## Fall and Fall-Related Injury Reporting

Falls and related injuries have consistently been associated with the quality of nursing care in the acute care setting. They are included as a nursing-quality indicator monitored by the American Nurses Association, National Database of Nursing Quality Indicators (ANA–NDNQI) and by the National Quality Forum.29, 30 Participation in the ANA–NDNQI provides hospitals with the ability to view their fall and injury rates in relation to other hospitals of similar type and size. However, participation in ANA–NDNQI is voluntary; despite a rapidly growing participation rate, it is not yet ubiquitous (1,089 hospitals as of June 2007, approximately 15 percent of U.S. hospitals). The National Quality Forum also advocates for voluntary reporting of quality indicators for acute care (falls prevalence and fall-related injuries) and ambulatory care (fall-risk screening for geriatrics).31, 32

The Maryland Quality Indicator Project is a second voluntary national repository that provides fall and fall-related injury benchmarks for the behavioral health, long-term care, and home care settings.33 Unfortunately, this project has a participation level of approximately 1,000 hospitals (approximately 14 percent), making national benchmarking difficult. In the home care setting, the Centers for Medicare & Medicaid Service’s Outcome and Assessment Information Set (CMS–OASIS) provides the reporting basis for the patients’ physical functioning.34 Growing efforts to expand patient safety initiatives to the home care setting seek to include falls as a quality indicator for patients who are cared for at home, but who are not completely bed bound.35, 36 Collection of these data has the potential for organizations to track fall rates of vulnerable patients and to identify patients at risk for falls and injuries. However, further research is required to validate such screening and to examine which interventions are effective based on risk status.

In the nursing home setting, the long-term care minimum dataset (LTCMDS) is used for reporting all aspects of care. The LTCMDS captures fall and injury histories via assessments that are performed on admission and at regular intervals during a resident’s stay.37 In addition, residents are evaluated for balance and for the ability to perform activities of daily living (ADLs), with the goal to apply fall-prevention measures should the patient be deficient in these areas. Recent research by Hill-Westmoreland and Gruber-Baldini38 indicated only a 75 percent concordance between chart abstraction and minimum dataset reporting for a group of long-term care facilities. A more recent development in the long-term care setting, the Nursing Home Quality Initiative, promotes the collection of a list of enhanced quality indicators, including those that track declines in functional and cognitive status.34, 37 The Agency for Healthcare Research and Quality (AHRQ) has elected to monitor only postoperative hip fracture as their fall-related preventive quality indicator, which is consistent with thinking that monitoring fall-related injuries is a more dependable measure of quality.39, 40 However, tracking of all fractures would be of benefit. The Health Plan Employer Data and Information Set has recently added Fall Risk Assessment to its dataset, which will provide a method to benchmark the evaluation of fall risk between health insurance providers.41 However, application of fall- and injury-prevention programs is not included as an indicator, which will make it difficult to benchmark these important measures. Increased and more accurate monitoring of these elements has the potential to reduce falls among nursing home residents; however, the effect of these efforts has yet to be established.

### Definitions of Falls and Fall-Related Injuries

Falls and related injuries have had varying definitions.42, 43 Falls may be precipitated by intrinsic or extrinsic factors. Intrinsic factors are those that have a physiologic origin, and extrinsic factors are those precipitating from environmental or other hazards. Distinguishing between intrinsic or extrinsic risk factors can facilitate identification of preventive strategies. According to Tinetti, Speechley, and Ginter,44 a fall in the nonhospitalized geriatric population is defined as “an event which results in a person coming to rest unintentionally on the ground or lower level, not as a result of a major intrinsic event (such as a stroke) or overwhelming hazard.” Agostini, Baker, and Bogardus45 adapted this definition for the inpatient, acute, and long-term care areas to define a fall as “unintentionally coming to rest on the ground, floor, or other lower level, but not as a result of syncope or overwhelming external force.”

Other definitions are broader and include falls related to intrinsic events such as syncope or stroke. For example, Nevitt’s46 definition of a fall is “falling all the way down to the floor or ground, or falling and hitting an object like a chair or stair.” The ANA–NDNQI provides an all-inclusive definition47 (p. 26):

An unplanned descent to the floor (or extension of the floor, e.g., trash can or other equipment) with or without injury. All types of falls are included, whether they result from physiological reasons or environmental reasons.

The International Classification of Diseases 9 Clinical Modifications (ICD-9-CM) uses several codes to categorize falls, all of which have broad descriptions: Accidentally bumping against moving object caused by crowd with subsequent fall (E917.6); Fall on or from ladders or scaffolding (E881); Fall from or out of building or other structure (E882); Other fall from one level to another (E884); Fall on same level from slipping, tripping, or stumbling (E885); Fall on same level from collision, pushing, or shoving by or with another person (E886); and Other and unspecified fall (E888).48 In the inpatient care setting, E888 is the code that is typically used to record a fall in a medical record. However, this ICD-9-CM code is not consistently used for reporting; therefore, institutions generally rely on incident reports as the method of counting fall events.48

Fall-related injuries in the community, home care, and long-term care areas are generally characterized by ICD-9-CM diagnoses for the related injured body part. In contrast, incident reports in the acute care setting use the following ANA–NDNQI fall-related injuries categories:

1. None indicates that the patient did not sustain an injury secondary to the fall.
2. Minor indicates those injuries requiring a simple intervention.
3. Moderate indicates injuries requiring sutures or splints.
4. Major injuries are those that require surgery, casting, further examination (e.g., for a neurological injury).
5. Deaths refers to those that result from injuries sustained from the fall.29

According to Morse,21 inpatient falls can be classified into three categories: accidental falls (derived from extrinsic factors, such as environmental considerations), anticipated physiologic falls (derived from intrinsic physiologic factors, such as confusion), and unanticipated physiologic falls (derived from unexpected intrinsic events, such as a new onset syncopal event or a major intrinsic event such as stroke). Morse asserts that using this classification, approximately 78 percent of the falls related to anticipated physiologic events can be identified early, and safety measures can be applied to prevent the fall. Research to identify precursors to unexpected intrinsic events, such as screening for predictors of syncopal events, might increase the early identification of anticipated physiologic falls, which could ultimately prevent more falls.49–51

### Falls and Fall-Related Injuries as Medical Errors

The definition of a fall is consistent with that of a medical error: “the failure of a planned action to be completed as intended” (i.e., error of execution) or “the use of a wrong plan to achieve an aim” (i.e., error of planning).52, 53 For example, an error of execution might be the failure to perform the planned action of placing a call light within the patient’s reach, and an error in planning might be to provide aggressive physical therapy before a patient's balance has been established. An error of commission is “an error that occurs as a result of an action taken,” for example, a fall that occurs subsequent to a behavioral health patient's electroconvulsive therapy. An error of omission, “an error which occurs as a result of an action not taken,” might occur if the patient is not assessed for fall and injury risk, which prevents appropriate interventions from being applied. Latent errors related to fall and injury prevention are those in which an agency does not apply appropriate standards, training, or support for the practice-based fall- and injury-prevention processes. Recent efforts by the Joint Commission (formerly the Joint Commission on Accreditation of Healthcare Organizations [JCAHO]) in its National Patient Safety Goals advocate for institution-wide risk assessment for falls and documentation of a fall-prevention program.54 These efforts have the potential to eliminate latent errors related to falls and injuries. Monitoring errorsmight occur if the patient is not monitored to identify fall risk, or if the patient is not monitored to identify a post-fall injury such as a subdural hematoma.

This review summarizes the current research related to fall and injury prevention. The chapter is organized to present research from two perspectives: (1) community setting, and (2) acute and long-term settings. For each setting, the research that addresses risk factors, risk assessment instruments, and fall- and injury-prevention interventions are reviewed. Reports on the outcomes of fall- and injury-prevention research using experimental or quasi-experimental research design is summarized in tables at the end of the chapter.

## Research Evidence

### Falls and Related Injuries in the Community

In the following section, research about falls and related injuries in the community were identified and categorized as follows: risk factor identification, risk assessment instruments, and prevention strategies.

#### Risk factors in the community

The pivotal research of Tinetti, Speechly and Ginter44 related to fall and injury prevention in community-dwelling individuals older than 65 years identified the following risk factors for falling: (1) postural hypotension, (2) use of any benzodiazepine or sedative-hypnotics, (3) use of four or more prescription medications, (4) environmental hazards, and (5) muscular strength or range of motion impairments. Other researchers have identified additional patient or treatment risk factors: (1) comorbidities, including diabetes, diabetic foot ulcer,55 stroke,56 syncope,57 anemia,58, 59 Alzheimer’s disease,60 Parkinson’s disease,61 vitamin D deficiency,62, 63 and vitamin D deficiency in combination with low creatinine clearance;64 (2) patient characteristics, including fallophobia (also known as “fear of falling”),65, 66 gait problems (e.g., weakness and impaired sensation),67 postural hypotension, inability to get out of chair, impaired ability to perform ADLs, frailty,68–70 inability to follow instructions,71 and inability to adapt to changing environment;72 and (3) other characteristics, including recent hospitalization,9 nonsupportive footwear (e.g., slippers),73 reckless wheelchair use,74 environmental hazards, and use of psychotropic medication.75, 76 Age and gender are also associated with falls and fall-related morbidity and mortality. Fall rates increase with age,77 and in community-dwellers between 65 and 85 years of age, females are more likely to fall, but males are more likely to die from fall-related injuries than females in this group.1, 2

The roles of ethnicity and race in relation to falls and injury have also been studied. Reyes-Ortiz and colleagues78 examined risk factors for Mexican-Americans and found that in the community, the risk factors are the same as for their White counterparts. Hanlon and colleagues79 examined predictors of falls between Caucasians and African Americans and found that African Americans were 23 percent less likely to fall than Whites (odds ratio = 0.77). Faulkner and colleagues80 explored this difference in women and found that Caucasian women were 50 percent more likely to fall than African American women, although this was not statistically significant (relative risk = 1.50, 95% confidence interval [95% CI] = 0.90–2.49). The researchers further examined situations leading to falls and found that circumstances differed by ethnicity: Caucasian women were more likely to fall outdoors versus indoors (odds ratio = 1.6, 95% CI = 1.0–2.7) and laterally versus forward (odds ratio = 2.0, 95% CI = 1.1–3.4), but less likely to fall on the hand or wrist (odds ratio = 0.6, 95% CI = 0.3–1.0). This research suggests that activities differ between older African American women and their Caucasian counterparts and should be considered when making fall- and injury-prevention plans.

#### Risk factors for injury in the community

Risk factors for injury in the community are increasingly well characterized. Porthouse and her research team81 performed a comprehensive cohort study of almost 4,300 women older than 70 years and confirmed the following risk factors for various types of fall-related fractures: (1) fall in the past 12 months, (2) increasing age, (3) previous fracture, and (4) low body weight. This work also identified that smoking was not associated with fracture risk. A growing body of research is examining vitamin D deficiency as a risk factor for fracture; however, results are conflicting to date, but bear further research.81, 82

Colon-Emeric and colleagues83 used data from a large community epidemiologic study to identify whether historical and functional information could help to predict fracture risk. The researchers identified nine characteristics that were predictors of fracture: (1) female sex, (2) age greater than 75 years, (3) White race, (4) body mass index (BMI) of less than 22.8 kg/m^2^, (5) history of stroke, (6) cognitive impairment, (7) one or more ADL impairments, (8) one or more Rosow-Breslau impairments (e.g., perform heavy work, walk a mile, climb stairs), and (9) antiepileptic drug use. Ohm and colleagues84 recently identified that elderly community-dwelling individuals with traumatic head injuries were more likely to die based on the use of antiplatelet therapy (relative risk = 2.5 for those taking antiplatelet therapies; P = 0.016). A similar body of research related to chronic subdural hematomas has identified that patients on anticoagulant or antiplatelet therapy are at higher risk for chronic subdural hematoma and that many of these are first identified when a patient is evaluated after a fall.85 Many injury risk factors are consistent with fall risk factors, accentuating the need for effective screening of elderly community-dwelling individuals. However, factors that make people more susceptible to injury, such as antiplatelet therapy, establish the need for additional safety measures for individuals at risk for injury. Table 1 lists the intrinsic and extrinsic risk factors for falls, injuries, and fall-related deaths in the community.

Table 1

Risk Factors for Falls, Injuries, and Fall-Related Deaths in the Community

Intrinsic Risk Factors | Fall Risk | Injury Risk | Mortality Risk
Demographics
• Age: Older Age (especially >70yrs) | Yes | Yes | Yes
• Gender | Female | Female | Male >85
• Race | Caucasian | Caucasian | Caucasian
Cognitive Function
• Cognitive impairment | Yes | No data | No data
• Fallophobia (fear of falling) | Yes | Yes | No data
• Inability to follow instructions | Yes | No data | No data
• Inability to adapt to changing environment | Yes | No data | No data
Physical Function
• Gait problems | Yes | No data | No data
• Impaired ability to perform ADLs | Yes | Yes | No data
• Impaired muscle strength or range of motion | Yes | Yes | No data
• Poor/fair self-reported health | Yes | Yes | No data
• Rosow-Breslau impairment | No data | Yes | No data
• Vision problems | Yes | No data | No data
Physical Status
• BMI less than 22.8 kg/m^2^ | No data | Yes | Yes
• Frailty | No data | Yes | Yes
• Low body weight (<58 kg=BMI 23 if height 5’3”) | Yes | Yes | No data
Comorbidities
• Alzheimer disease | Yes | No data | No data
• Anemia (including mild anemia) | Yes | No data | No data
• Diabetes | Yes | No data | No data
• Diabetic foot ulcer | Yes | No data | No data
• Fall in the past 12 months | Yes | Yes | No data
• Parkinson disease | Yes | No data | No data
• Postural hypotension | Yes | No data | No data
• Previous fracture | No data | Yes | No data
• Stroke | Yes | Yes | No data
• Subdural hematoma (chronic) | Yes | Yes | No data
• Syncope | Yes | No data | No data
• Vitamin D deficiency | Yes | Yes | No data
• Vitamin D deficient w/low creatinine clearance | Yes | No data | No data
Medications
• Use of 4 or more medications | Yes | No data | No data
• Anti-epileptics | No data | Yes | No data
• Antihypertensives | Yes | No data | No data
• Antiplatelet therapy | No data | No data | Yes
• Psychotropics | Yes | No data | No data
• Sedatives and hypnotics | Yes | No data | No data
Extrinsic Risk Factors | Fall Risk | Injury Risk | Mortality Risk
• Environmental hazards | Yes | No data | No data
• Footwear, non-supportive (e.g., slippers) | Yes | No data | No data
• Hospitalization, recent | Yes | No data | No data
• Wheelchair use, reckless wheelchair use | Yes | No data | No data

#### Risk assessment instruments for community dwellers

Tinetti86 developed a fall risk assessment index based on the following nine risk factors: mobility, morale, mental status, distance vision, hearing, postural blood pressure, back examination, medications, and ability to perform ADLs. This instrument has been the most widely used and tested, with a reported sensitivity of 80 percent and specificity of 74 percent.87 Other instruments used in the community include the following (with reported sensitivities and specificities in parentheses): (1) Berg Balance Test (sensitivity = 77 percent; specificity = 86 percent), (2) Elderly Fall Screening Test (sensitivity = 93 percent; specificity = 78 percent), (3) Dynamic Gait Index (sensitivity = 85 percent; specificity = 38 percent), and (4) Timed Get Up and Go test (sensitivity = 87 percent; specificity = 87 percent).87 Aside from the Timed Get Up and Go test, which takes less than a minute for a health care provider to administer, these instruments generally take 15 to 20 minutes to complete.87

Lord and colleagues88 recently evaluated the effect of an exercise-related fall-prevention program, but found that the intervention was not useful in community dwellers who were not screened for risk. The researchers concluded that screening to identify individuals at high risk for falls would be necessary for a successful fall-prevention program. Further research to identify the most accurate, yet easy-to-use risk assessment instrument would be necessary to move these efforts forward.

A recent systematic review by Scott and colleagues89 examined fall risk assessment instruments in the community. The authors concluded that, in general, risk assessment instruments are available; however, most have been tested in only one setting. Therefore, further validation studies should be conducted on fall risk assessment instruments before any specific instrument can be recommended.

A potential time point for risk assessment is in the emergency department (ED). Several researchers have examined the effect of fall- and injury-prevention interventions applied to patients who are discharged from the ED after a noninjury or nonserious-injury fall. The overarching goal of these studies is to evaluate the ability of comprehensive risk assessment followed by targeted interventions to prevent future falls and fall-related injuries. Several studies have successfully shown that screening followed by tailored management can decrease repeat falls.42, 90–94 Close and colleagues42 found that fall rates were reduced by 61 percent and recurrent falls were reduced by 67 percent for patients who had comprehensive risk assessment after a fall, compared to individuals who received standard treatment. Davison and colleagues90 found a 36 percent decrease in fall rates after 1 year for patients who received a multimodal intervention for fall prevention after being identified as a faller on admission to the ED. In addition, these researchers noted an increase in falls self-efficacy, which is a measure of an individual’s perception of their ability to manage situations where they are at high risk for falling – the higher self-efficacy, the more able a person is able to manage high risk situations. In a related study, Lee, Hurley, and colleagues91 conducted a randomized controlled trial to examine the impact of a personal emergency response system and found that there was no difference between treatment and control groups for self-efficacy or patient anxiety. The Lee and colleagues study is informative in that emergency contact alone was not sufficient to improve a patient’s belief in their ability to manage fall risk situations. Although no standardized instrument has yet been developed for use in the ED environment, the potential for the prevention of falls and related injuries in the community would be increased with the accurate identification of patients at risk for falls while they are in the ED.

#### Automated risk assessment in the community setting

To date, a limited number of computer-based, community-based fall assessment instruments have been described. By far the most complex and integrated is the Fall Risk Assessment and Management System, which was developed by the Australia Family Practice Group for use in the community by family practice physicians.95 Fall Risk Assessment and Management System includes automated recommendations after the clinician executes a thorough patient assessment. Although this system appears promising, its efficacy has not yet been reported.

Lord, Menz, and Tiedemann96 describe an electronic fall risk assessment instrument that provides a method to measure several risk factors, including vision, peripheral sensation, muscle force, reaction time, and postural sway. Although this instrument is thorough, it is meant for use by a physical therapist or a physician, nurse practitioner, or physician assistant for a focused fall risk assessment, rather than as a triage or screening tool. The novel aspect of this instrument is the comparison of the individual’s score to the normative scores for each of the assessments, which provides the clinician with an anchor and may facilitate improved screening over time. However, the predictive validity of this instrument has not been reported, and its use may be limited to a fall-prevention clinic.

Another electronic fall risk assessment instrument, described by Dyer and colleagues,97 is an electronic checklist in a fall-prevention clinic. Unfortunately, the researchers concluded that the clinic itself was more successful than the instrument in identifying risk factors for falling, underscoring the reality that the implementation of an instrument without associated policy and procedure changes may have limited effect.

The presence of these automated systems indicates that there is movement toward computerized fall risk assessment. Indeed, many clinical information systems have adapted paper-based assessment instruments for use in the acute care setting. However, the efficacy of these systems has not been reported, and their effectiveness is likely to be constrained by the limits of the original instrument, the system in which they are placed, and the design team in ensuring that the automated instrument accurately reflects the original instrument.

#### Prevention strategies in the community

To date, several reviews conducted to examine the evidence available to support practice in this area have identified the need for multimodal, interdisciplinary prevention programs; the need for more accurate risk assessment instruments; and the need for more research related to this complex and costly problem.11, 98–107

Cumming100 reviewed 21 trials and concluded that exercise programs were the most promising, and reduction of antipsychotic medications should be considered. However, Cumming also concluded that none of the reviewed research studies provided a definitive prevention strategy. Chang and collaborators99 conducted a similar review targeted at examining interventions for older adults in the community and found that multimodal assessments with targeted intervention reduced risk of falls by 37 percent, and that exercise interventions reduced fall risk by 14 percent. Hill-Westmoreland, Soeken, and Spellbring38 conducted a recent meta-analysis, including a sensitivity analysis, which identified an improved effect on fall prevention in the community when individualized management was added to exercise interventions. They concluded that exercise interventions were not sufficient in and of themselves, and interventions needed to be tailored to address individual risk factors.

Researchers have explored several other individual prevention strategies, including fall prevention clinics, exercise interventions with leg strengthening (e.g., Tai Chi), vitamin D supplements, home visits for safety evaluations, cataract surgery, and cardiac pacing. Falls and balance clinics present a promising community-based solution to the problem of falls.108 Perell and colleagues109 found a 50 percent reduction in fall rates for patients who were screened at a clinic and who had tailored interventions applied; however, this study had no control group and the researchers did not report injury rates, so the results are tentative. Clinics such as these provide focused intervention planning for patients identified at risk for falling, but the success of such clinics is contingent upon accurate identification of high-risk patients.

Identification of recurrent fallers via comprehensive screening followed by tailored interventions has been successful at reducing recurrent falls. Screening and intervention done in the ED reduced recurrent falls by 36 percent in one study,90 and a nurse-led intervention that provided home assessment and tailored interventions reduced recurrent falls by 38 percent in another study.110 Hogan and colleagues111 also evaluated tailored interventions for patients who had had a fall within the past 3 months. They found no significant differences between the intervention and control groups in fall rates or time to first fall; however, the intervention group had a longer time between falls (P = 0.001). However, the Hogan and colleagues study limited inclusion criteria to patients older than 65 years of age who had fallen in the past 3 months, and these two factors alone are likely insufficient to determine risk. These recent studies add to early work in the PROFET study, which found a 61 percent decrease in falls for patients who were identified in the ED and who had subsequent detailed risk assessment and tailored interventions.42

Exercise-related interventions are by far the most commonly studied individual community prevention strategy. Most of this research indicates that exercise is beneficial for patients, and some research demonstrates that exercise regimes that involve leg strengthening and balance training, such as Tai Chi, are most effective.112–122 Robertson and colleagues123 performed a meta-analysis of four studies that examined effects of home exercise programs. They found in the pooled effect analysis that both fall and injury rates decreased by 35 percent. Exercise in conjunction with cognitive behavioral therapy, where patients are taught how to increase self-awareness about risky situations, has demonstrated promising results, including a longer time to first fall and decreased injuries.124 Unfortunately, this work did not demonstrate an effect on falls efficacy, fear of falling, or actual fall rates. More recently, balance training has been compared to general exercise, and results show that balance training can prevent falls in the nonfrail elderly, but not in the frail elderly.125 Lin and colleagues126 found that deployment of large scale Tai Chi training to the general community had mixed results. Luukinen and colleagues127 found a decrease in fall and injury rates with a targeted exercise program when compared to usual care, but the results were statistically significant only in a group that was not homebound—suggesting that early intervention may be more effective. Further research to explore interventions for homebound community dwellers, particularly for the very old and frail, will be important.

Laboratory studies indicate that calcium and vitamin D reduce bone loss,128 and a growing body of work is examining the ability for vitamin D supplementation to prevent fractures in individuals who are vitamin D deficient. A meta-analysis performed by Bischoff-Ferrari and team129 revealed that larger doses of vitamin D supplementation (700–800 IU/deciliter) reduced the risk of fracture by up to 26 percent, whereas smaller doses of vitamin D (400 IU/deciliter) did not reduce fracture risk. However, research to date has been inconclusive, and larger, more recent studies have indicated that the use of vitamin D does not reduce fracture risk in the general community.130 On the other hand, vitamin D supplementation may be integral in preventing falls themselves:131 Recently, Latham and colleagues132, 133 demonstrated that vitamin D intake is an individual predictor for fall reduction, primarily by improving muscle strength. Bischoff-Ferrari and colleagues134 have also identified a reduction in fall risk for women, but not for men, using vitamin D supplementation. Although these results are promising, more research is required to identify best practice recommendations related to vitamin D deficiency screening and vitamin D supplementation or other bone-supporting medication regimes.

Other researchers are exploring the ability for osteoporosis-prevention medications to reduce fracture risk.135 Sato and colleagues136, 137 reported that risedronate, an oral bisphosphonate for osteoporosis prevention, was effective at preventing fracture in older females, older males who have had a stroke, and older females with Alzheimer’s disease. A recent large study by McCloskey and colleagues138 (N = 5579) demonstrated a 20–29 percent decrease in clinical fractures in community-dwelling females older than 75 years with and without osteoporosis who were prescribed clodronate 800 mg daily. However, this study did not find a decrease in hip fractures. Recent reports of adverse side effects of large doses of bisphosphonates, including osteonecrosis of the jaw, indicate that further research is warranted and that patients should be monitored for side effects of these drugs. Other related fall prevention efforts include home assessment for risk factors with the implementation of safety devices such as handrails, nonslip surfaces on stairs, and removal of throw rugs.139–143 Researchers who conducted a recent randomized controlled trial found that thin-soled shoes were found to be the best type of shoe for patients, rather than running shoes, which have sticky soles.144 Research addressing syncope-related falls indicate that cardiac pacing may be appropriate for individuals with syncope.145

#### Summary of community-based research on falls and related injuries

In summary, authors of several reviews have examined the efficacy of community-based fall- and injury-prevention programs. These reviewers have indicated that individualized multimodal interventions are effective at reducing falls and related injuries in the community setting.105 However, multimodal interventions are not in place across primary care areas, which hinders their potential efficacy, and the aging community would likely benefit from large-scale implementation of these proven preventive interventions. (See Evidence Tables 1 through 9 for individual study results.)

Evidence Table 1

Reviews Examining Fall-Prevention Interventions in the Community

Source | Safety Issue Related to Clinical Practice | Design Type^*^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Weigand 2001^93^ | Fall and injury prevention in the community | Literature Review | Design: Review Outcomes: Fall rates | Setting: Community Population: Emergency patients | Assessment of fallers & targeted interventions | Falls: No definitive evidence to support ED assessment followed by targeted interventions is effective for preventing falls. More research required.
Cumming 2002^100^ | Fall and injury prevention in the community | Literature Review | Design: Review Outcomes: Fall rates | Setting: Community Population: Older adults | Multiple interventions; 21 trials reviewed | Falls:; - Exercise programs most promising.; - Reduction of antipsychotic medications should be considered.; - No definitive prevention strategy.
Gillespie 2003^104^ | Fall and injury prevention in the community | Meta-analysis | Design: Systematic Review Outcomes: Fall rates | Setting: Community Population: 21,668 people | Multiple interventions; 62 trials reviewed | Falls: Multimodal, interdisciplinary prevention programs are most successful. Risk Assessment: Need more accurate risk assessment instruments.
Chang 2004^99^ | Fall and injury prevention in the community | Meta-analysis | Design: Review Outcomes: Fall rates | Setting: Community Population: Older adults | Multiple interventions; 40 trials reviewed | Falls: Multimodal assessments with targeted intervention reduced risk of falls by 37 percent, and exercise interventions reduced fall risk by 14 percent.
Hill-Westmoreland 2005^38^ | Fall and injury prevention in the community | Meta-analysis | Design: Meta-analysis Outcomes: Fall rates | Setting: Community Population: Older adults in long-term care setting | Multiple interventions; 12 studies reviewed | Falls: Decrease in fall rates when individualized management added to exercise interventions.
Stevenson 2005^135^ | Fall and injury prevention in the community | Systematic Review | Design: Systematic review Outcomes: Fracture, vertebral and nonvertebral | Setting: Community Population: Older women at risk for fracture | Review of calcium, vitamin D, and bisphosphonates | Fractures:; - Calcium, with or without vitamin D, reduces fractures in patients with high risk for fracture.; - Calcium with vitamin D can prevent fractures in women not at risk for fractures.
Shekele 2003^11^ | Fall and injury prevention in the community | Meta-analysis | Design: Meta-analysis Outcomes: Fall and injury rates | Setting: Community Population: Medicare recipients | Mulriple interventions | Falls: Multifactorial fall prevention programs decrease fall rates

* Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 2

Studies on Community-Based Fall-Prevention Screening with Tailored Interventions (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^†^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Close 1999^42^ | Tailored interventions for falls in the community | RCT | Design: RCT Outcomes: Fall rates, repeat fall rates, hospital admissions, Barthel Score (Max 100; higher score = higher functioning) | Setting: Community Population: 397 patients ≥ 65 years who presented to an accident and emergency department with a fall | Detailed medical and occupational-therapy assessment with referral to relevant services if indicated with 1 year followup. | Falls: Decreased by 61 percent for patients who were identified in the emergency department and who had subsequent detailed risk assessment and tailored interventions (odds ratio = 0.39, 95% CI = 0.23–0.66; P = 0.0002). Recurrent falls: Decreased by 67 percent (odds ratio = 0.33, 95% CI = 0.16–0.68). Hospital admissions: Decreased by 39 percent (odds ratio = 0.61, 95% CI = 0.35–1.05). Barthel score: Decline in score with time greater in the control group (P < 0.00001).
Hogan 2001^111^ | Tailored interventions for falls in the community | RCT | Design: Randomized controlled trial Outcomes: Fall rates, repeat fall rates, time between falls, emergency department visits, hospital admissions | Setting: Community Population: 152 patients ≥ 65 years who had fallen within the previous 3 months | In-home assessment in conjunction with the development of an individualized treatment plan, including an exercise program for those deemed likely to benefit. | Cumulative number falls: No significant differences (311 v. 241, P = 0.34) One or more falls: No significant difference (79.2 percent v. 72.0 percent, P = 0.30) Mean number of falls: 4.0 v. 3.2, P = 0.43. Repeat fall rates: No significant difference Time between falls: Longer time between falls in intervention group (P < 0.001) For multiple fallers at baseline:; - Intervention group less likely to fall (P = 0.046); - Time between falls longer for intervention group (P < 0.001); Emergency department visits: No significant difference Hospital admissions: No significant difference
Lightbody 2002^110^ | Tailored interventions for falls in the community | RCT | Design: RCT Outcomes: Falls, functional ability, emergency department visits, admission to hospital | Setting: Community Population: 348 consecutive patients ≥ 65 years who were discharged from emergency room after sustaining a fall | Home assessment for medication, ECG, blood pressure, cognition, visual acuity, hearing, vestibular dysfunction, balance, mobility, feet and footwear | Recurrent Falls: Reduced by 38 percent Falls: Decreased falls in intervention group, but not statistically significant. Admissions and bed days: Fewer fall-related admissions and bed days in intervention group (8 and 69, respectively) than the control group (10 and 233, respectively).
Nikolaus 2003^141^ | Tailored interventions for falls in the community | RCT | Design: RCT Outcomes: Number of falls, compliance with recommendations | Setting: Patients identified in university-affiliated geriatric hospital; intervention carried out in patients’ homes Population: 360 patients showing functional decline, especially in mobility, admitted to a geriatric hospital (mean age 81.5 years) | Comprehensive geriatric assessment followed by diagnostic home visit and home intervention or a comprehensive geriatric assessment with recommendatio ns | Falls: Intervention group had 31 percent fewer falls than control group (incidence rate ratio = 0.69, 95% CI = 0.51–0.97). Falls: For subgroup with ≥2 falls during previous year, there was a 37 percent decrease in falls (incident rate ratio = 0.63, 95% CI = 0.43–0.94).
Nitz 2004^108^ | Tailored interventions for falls in the community | RCT | Design: pilot RCT Outcomes: Fall rates, balance measures | Setting: Australia; academic medical center Population: 73 adults (92 percent female) ≥ 65 yrs | Balance training sessions once a week for 10 weeks | Falls: Intervention and control groups both showed reduction in fall rates, but no differences between groups. Balance measures: Improved for intervention group.
Davison 2005^90^ | Tailored interventions for falls in the community | RCT | Design: RCT Outcomes: Fall rates, number of fall-related admissions, LOS, balance | Setting: Accident & emergency departments in a teaching hospital and associated general hospital in the United Kingdom Population: 313 cognitively intact patients ≥ 65 years with fall or fall-related injury and at least one additional fall in preceding year | Multimodal postfall assessment, including medical, physiotherapy, and occupational therapy evaluation | Falls: 36 percent fewer falls in the intervention group (relative risk = 0.64, 95% CI = 0.46–0.90). Proportion of fallers: 65 percent of subjects in the intervention group continued to fall compared with 68 percent in the control group (relative risk = 0.95, 95% CI = 0.81–1.12). Hospital admissions: Number of fall-related visits and hospital admissions was not different between groups. Hospitalization: Duration of hospital admission was reduced (mean difference admission 3.6 days, 95% CI = 0.1–7.6). Activities-specific balance confidence score: Improved in the intervention group.
Perell 2006^109^ | Tailored interventions for falls in the community | Pretest post-test design | Design: Pretest, post-test Outcomes: Falls, repeat falls | Setting: Urban Los Angeles – Veterans Affairs System Population: 120 elders referred to the clinic. Gender not reported. | Screening following by tailored interventions at falls clinic | Falls: Reduction of total falls (pre = 297; post = 141; P = 0.0002). Increase in falls reported by 12.5 percent patients. Mean fall rates: Reduction in mean falls (pre = 4.1;post = 2.0). Repeat falls: Reduction in repeat falls (pre = 86 percent; post = 51 percent).

† Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 3

Studies Examining Exercise-Related Interventions in the Community (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^‡^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Reinsch 1992^124^ | Exercise-related interventions for fall prevention in the community | RCT | Design: Four-arm RCT Outcomes: Fall rates, time to first fall, injury rates | Setting: 16 senior centers in Orange County, California Population: 230 older adults who were participants at senior centers | Exercise in conjunction with cognitive behavioral therapy for safety self-awareness | Falls: No effect on fall rates, falls efficacy, or fear of falling. Time to first fall: Longer time to first fall. Injuries: Decreased injuries. Even though a relatively high percentage (38.6 percent) suffered at least one fall, only 7.8 percent of these community-residing elderly required medical attention.
Province 1995^115^ | Exercise-related interventions for fall prevention in the community | Meta-analysis | Design: Preplanned meta-analysis of 7 RCTs Outcomes: Time to each fall (fall-related injury) by self-report and/or medical records | Setting: Two nursing homes and five community sites Population: Patients ages 60–75, ambulatory, cognitively intact | Exercise training one area or more of endurance, flexibility, balance platform, Tai Chi (dynamic balance), and resistance | Falls:; - Fall rates decreased in group with general exercise (odds ratio = 0.90, 95% CI = 0.81–0.99).; - Fall rates decreased for those with exercise plus balance training (odds ratio = 0.83, 95% CI = 0.70–0.98).; Injuries: Patients who did not exercise had an increase in injurious falls, but power was low to detect this outcome.
Wolf 1997^120^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Frailty indicators, occurrence of falls | Setting: Community Population: 200 men and women ≥ 70 years | Tai Chi, computerized balance training, or education | Multiple falls: Risk of multiple falls decreased by 47.5 percent
Steinberg 2000^143^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT with four arms Outcomes: Self-reported slips, trips, or falls | Setting: Community, Australia Population: 252 active, community-dwelling Australians ≥ 50 yrs. | Education re: fall risk factors, strength/balance exercises, home safety advice, medical evaluation | Falls: 30 percent reduction in falls; hazard ratio 0.70 (95% CI = 0.48–1.01). Slips: 58 percent reduction in slips; hazard ratio 0.42 (95% CI = 0.29–0.69). Trips: 64 percent reduction in trips; hazard ratio 0.36 (95% CI = 0.26–0.66).
Rubenstein 2000^116^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Muscle strength, endurance, mobility, balance, fall rates | Setting: Community-living men Population: 59 men ≥ 65 years with specific fall risk factors | 90 min. exercise sessions 3x/week Focus on increased strength and endurance, improving mobility and balance | Falls:; - Exercise group had lower fall rates than nonexercisers when adjusted for baseline activity level (6 falls/1,000 hours of activity vs 16.2 falls/1,000 hours, P < 0.05).; - Total number of falls not decreased.; Strength: Exercise achieved no significant effect on hip or ankle strength, balance, self-reported physical functioning.
Robertson 2002^123^ | Exercise-related interventions for fall prevention in the community | Meta-analysis | Design: Meta-analysis of four studies Outcomes: Fall rates, injury rates | Setting: Community setting: nine cities and towns in New Zealand Population: 1,016 women and men ages 65 to 97 | Muscle strengthening and balance retraining exercises designed specifically to prevent falls | Falls and injuries: Fall and injury rates decreased by 35 percent; no difference between genders.; - Fall rate incidence rate ratio (IRR) = 0.65, 95% CI = 0.57–0.75; - Participants reporting a fall in the previous year had a higher fall rate (IRR = 2.34, 95% CI = 1.64–3.34).; - Injury rate IRR = 0.65, 95% CI = 0.53–0.81.
Barnett 2003 113 | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Fall rates, balance, muscle strength, fear of falling | Setting: Community, South Western Sydney, Australia. Population: 163 subjects ≥ 65 years identified as at risk of falling using a standardized assessment screen by general practitioner or physical therapist | Weekly group exercise program with ancillary home exercises over 1 year | Falls: Fall rates decreased by 40 percent in the exercise group (IRR = 0.60, 95% CI = 0.36– 0.99). Balance measures: Improved in exercise group. Other measures: No difference between groups in strength, reaction time, and walking speed or on Short-Form 36, Physical Activity Scale for the Elderly or fear of falling.
Wolf 2003^122^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Time to first fall, fall rates, balance | Setting: 20 congregate living facilities in the greater Atlanta area Population: 291 women and 20 men ages 70 to 97 who were transitioning to frailty | Intense Tai Chi exercise program or wellness education program | Falls: Fall rates decreased in Tai Chi group, but no statistical difference between groups (relative risk = 0.75, 95% CI = 0.52–1.08).
Clemson 2004^114^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Fall rates | Setting: Community Population: 310 men and women ≥ 70 years who had had a fall in the previous 12 months or were concerned about falling | Occupational therapy home visits, lower-limb balance and strength training, environmental safety education | Falls:; - 31 percent reduction in falls for both genders (relative risk = 0.69, 95% CI = 0.50–0.96; P = 0.025).; - For men alone, 68 percent reduction in falls (relative risk = 0.32, 95% CI = 0.17–0.59).
Morgan 2004^140^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Falls | Setting: Community Population: 294 men and women ≥ 60 years who had either a hospital admission or bed rest for 2 days or more within the previous month | Exercise sessions lasting 45 minutes, including warm-up and cool-down, 3 times a week for 8 weeks (24 sessions) | Falls:; - 49 percent reduction in falls for patients with low baseline physical functioning.; - 3.5 times increase in falls for patients with high baseline physical functioning.
Suzuki 2004^118^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Fall rates | Setting: Community, Japan Population: 52 elderly Japanese women | Exercise intervention— home and community center | Falls: Fall rates decreased in intervention group (13.6 percent v. 54.5 percent; P = 0.0097).
Li 2005^112^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcome: Fall rates, functional balance, physical performance, fear of falling | Setting: Community in Portland, Oregon Population: 256 physically inactive elders ages 70 to 92 | Tai Chi or stretching 3x/week for 6 months | Falls: 55 percent reduction in falls in Tai Chi group (relative risk = 0.45, 95% CI = 0.30–0.70). Fewer falls in the Tai Chi group (Tai Chi = 38 vs. stretch = 73; P = 0.007), (Tai Chi = 28 percent vs. stretching = 46 percent; P = 0.01). Injuries: Fewer injurious falls (Tai chi = 7 percent vs. stretching = 18 percent; P = 0.03).
Lord 2005^88^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcome: Fall rates | Setting: Community in Australia Population: 620 people ≥ 75 years | Interventions to maximize vision and sensation or brief advice or usual care | Falls: The rate of falls during the trial period were similar in the three groups. Injuries: The rate of injurious falls during the trial period were similar in the three groups.
Faber 2006^125^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Falls, mobility, physical performance, and self-reported disability | Setting: 15 homes for the elderly in Amsterdam, The Netherlands Population: 287 elderly men and women (mean age +/− standard deviation, 85+/− 6yrs) | 20-week exercise program of balance training inspired by Tai Chi or daily mobility activities or control | Falls: Fall incidence rate lower in balance training group (2.4 falls/yr) compared to the mobility activities group (3.3 falls/yr) and control (2.5 falls/yr), but not statistically significant. For frail subjects: Risk of becoming a faller in the exercise groups increased almost 3 times (hazard ratio = 2.95; 95% CI = 1.64–5.32). For pre-frail subjects: Risk of becoming a faller decreased by 61 percent (hazard ratio = 0.39; 95% CI = 0.18–0.88).
Lin 2006^126^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Falls, fall-related injuries, related functional outcomes | Setting: 6 rural villages in Taiwan: 2 villages received intervention, 4 villages acted as controls Population: 1,200 men and women ≥ 65 years screened; 88 participants | Tai Chi training plus fall-prevention education or fall-prevention education alone | Falls: 50 percent greater decrease in fall rates among the Tai Chi practitioners (relative risk = 0.5; 95% CI = 0.11–2.17), but not statistically significant. Tinetti Balance Scale: Tai Chi practitioners increased by 1.8 points (95% CI = 0.2–3.4). Tinetti Gait Scale: Tai Chi practitioners increased by 0.9 point (95% CI = 0.1–1.8). Fear of Falling: No significant changes in the fear of falling.
Luukinen 2007^127^ | Exercise-related interventions for fall prevention in the community | RCT | Design: RCT Outcomes: Fall rates, time to first fall | Setting: Community, home-dwelling Finnish Population: 555 older men and women (67 percent ≥ 85 years), most with history of recurrent falls or at least one mobility risk factor | Suggestions for a program consisting of home exercise, walking exercise, group activities, self-care exercise, or routine care | For all subjects: Falls:; - 12 percent decrease in falls from baseline for intervention group (hazard ratio = 0.88, 95% CI = 0.74–1.04).; - 7 percent decrease in all falls, but not statistically significantly (hazard ratio = 0.93, 95% CI = 0.80–1.09).; For subjects not homebound: Falls:; - 22 percent decrease in falls (hazard ratio = 0.78, 95% CI = 0.64–0.94).; - 12 percent decrease in first four falls (hazard ratio = 0.88, 95% CI = 0.74–1.05).

‡ Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 4

Studies examining physiologic interventions in the community (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^§^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Latham 2003^132^ | Physiologic interventions to prevent falls in patients discharged from acute care to the community | RCT | Design: RCT Outcomes: Falls over 6 months | Setting: Five hospitals in Auckland, New Zealand, and Sydney, Australia Population: 243 frail older people (53 percent female) | One dose vitamin D 300,000 IU versus placebo OR 10 weeks of high-intensity home-based exercise versus attention lessons | Falls:; - Increase in falls for patients receiving vitamin D as compared to placebo, but not statistically significant (relative risk = 1.12, 95% CI = 0.79–1.59).; - Decrease in falls for patients in exercise group compared to attention group, but not statistically significant (relative risk = 0.96, 95% CI = 0.67–1.36).; Injury: Patients in the exercise group were at increased risk of musculoskeletal injury (risk ratio = 3.6, 95% CI = 1.5–8.0).
Bischoff-Ferrari 2004^178^ | Physiologic interventions to prevent falls and fall-related injuries in the community | Meta-analysis | Design: Meta-analysis of five RCTs Outcomes: Fracture | Setting: Community Population: 1,237 participant in the five studies | Vitamin D: Large dose = 700–800IU/d Small dose = 400 IU/d | Falls: Compared with patients receiving calcium or placebo, vitamin D reduced risk of falling by 22 percent (corrected odds ratio = 0.78, 95% CI = 0.64–0.92). Fracture:; - Vitamin D 700–800IU/d reduced the risk of fracture by up to 26 percent.; - Vitamin D 400 IU/d did not reduce fracture risk.; Numbers needed to treat: 15 patients would need to be treated with vitamin D to prevent 1 person from falling. Sensitivity analysis of 5 additional studies: Total sample 10,001 – smaller effect size (corrected relative risk = 0.87, 95% CI = 0.80–0.96).
Avenell 2005^107^ | | Meta-analysis | Design: Metanalysis of RCTs or quasi-randomized trials Outcomes: Fractures | Setting: Community Poplulation: 7 trials; 18,668 participants | Vitamin D or an analogue alone, or vitamin D with calcium, or Placebo, no intervention, or calcium | Vitamin D or analogue alone:; - No effect on hip fracture (relative risk = 1.17; 95% CI = 0.98–1.41).; - No effect on vertebral fracture (relative risk = 1.13; 95% CI = 0.50–2.55).; - Any new fracture (relative risk = 0.99; 95% CI = 0.91–1.09).; Vitamin D or analogue with calcium:; - Marginal reduction in hip fractures (relative risk = 0.81; 95% CI = 0.68–0.96).; - Marginal reduction in nonvertebral fractures (relative risk = 0.87; 95% CI = 0.78–0.97).; - No effect on vertebral fractures.; - Calcitriol may be associated with an increased incidence of adverse effects.
Grant 2005^130^ | Physiologic interventions to prevent falls and fall-related injuries in the community | RCT | Design: Factorial-design trial Outcomes: New low-energy fractures | Setting: Patients identified in 21 UK hospitals then treated at home after discharge Population: 5,292 people ≥ 70 years (85 percent female) with new low-trauma fracture, and who were mobile before that fracture | 800 IU vitamin D daily or 1,000 mg calcium daily or 800 IU vitamin D plus 1,000mg calcium daily or placebo | Falls: No differences between groups (hazard ratio = 0.94; 95% CI = 0.81–1.09). Fractures:; - No difference between vitamin D and placebo (hazard ratio = 1.02; 95% CI = 0.88–1.19).; - No difference between combination treatment and placebo.
Sato 2005^137^ | Physiologic interventions to prevent fall-related injuries in acute care | RCT | Design: RCT Outcomes: Vertebral factures, hip fractures | Setting: Community in Japan Population: 500 women ≥ 70 years with Alzheimer’s disease, vitamin D deficiency, and hyperparathyroidism | Risedronate 2.5 with 1,000 IU vitamin D plus 1,200 mg calcium or placebo with 1,000 IU vitamin D plus 1,200 mg calcium | Fractures: 72 percent decrease in fractures in the risedronate group (relative risk = 0.28; 95% CI = 0.13–0.59).
Bischoff-Ferrari 2006^134^ | Physiologic interventions to prevent falls and fall-related injuries in the community | RCT | Design: RCT Outcomes: Fall rates | Setting: Community Population: 199 men and 246 women ≥ 65 years living at home | 700 IU of vitamin D plus 500 mg of calcium citrate malate per day or placebo | Falls:; - Vitamin D plus calcium reduced the odds of falling in women by 46 percent (odds ratio = 0.54, 95% CI = 0.30–0.97).; - Vitamin D plus calcium reduced the odds of falling in women by 65 percent in less active women (odds ratio = 0.35; 95% CI = 0.15– 0.81).; - Vitamin D plus calcium did not significantly reduced the odds of falling in men (odds ratio = 0.93, 95 percent CI, 0.50–1.72)
McCloskey 2007^138^ | Physiologic interventions to prevent falls and fall-related injuries in the community | RCT | Design: RCT (double-blind) Outcomes: Hip and any clinical fracture | Setting: General community in South Yorkshire and North Derbyshire Population: 5,579 women ≥ 75 years | 800 mg oral clodronate (Bonefos) or placebo | Hip fracture: Slight increase in risk for hip fracture in placebo group (hazard ratio = 1.02, 95% CI = 0.71–1.47). Any fracture: 20 percent decrease in risk for any clinical fracture for patients in clodronate group (hazard ratio = 0.80, 95% CI = 0.68–0.94). Osteoporosis-associated nonhip fractures: 29 percent decrease in clodronate group (hazard ratio = 0.71; 95% CI = 0.57–0.87).

§ Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 5

Reviews Examining Fall Prevention Interventions in Acute and Long-Term Care (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^**^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Evans 1998^153^ | Fall and injury prevention in the acute care setting | Literature Review | Design: Review Outcomes: Fall rates | Setting: Acute care Population: Patients in acute care setting | Multiple interventions; 200 studies reviewed | Falls: Across settings, individual interventions are not more useful than fall-prevention programs for a specific subset of patients.
Oliver 2000^234^ | Fall and injury prevention in the acute care setting | Meta-analysis | Design: Systematic review Outcomes: Fall rates | Setting: Acute care Population: Patients in acute care setting | Multiple interventions; 10 studies reviewed | Falls: Overall the interventions studied did not prevent falls (pooled effects ratio = 1.0; 95% CI = 0.60–1.68).
Agostini 2001^98^ | Fall and injury prevention in the acute care setting | Review | Design: Review Outcomes: Fall rates | Setting: Acute care Population: Patients in acute care setting | Multiple interventions; two studies and one systematic review reviewed | Falls: Interventions with potential to decrease falls include identification bracelets, bed alarms, special flooring, and hip protectors.
Oliver 2007^235^ | Fall and injury prevention in the acute care setting | Meta-analysis | Design: Systematic review Outcomes: Fall rates, fall-related fracture rate | Setting: Acute care Population: Patients in acute and long-term care setting | Multiple interventions; 43 studies included in meta-analysis | Falls:; - Multimodal interventions in hospitals showed 18 percent decrease in fall rates (rate ratio = 0.82; 95% CI = 0.68–0.997).; - Multimodal interventions in hospitals showed no significant effect on the number of fallers. njuries: I; - Hip protectors in long-term care homes showed a 33 percent decrease in hip fractures (rate ratio = 0.67; 95% CI = 0.46–0.98).; - Multimodal interventions in hospitals showed no significant effect on the number of fractures.; Other interventions: Insufficient evidence to recommend other interventions.

** Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 6

Studies Examining Environmental Interventions in Acute and Long-Term Care (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^††^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Tideiksaar 1993^154^ | Environmental interventions for fall prevention in acute and long-term care | RCT | Design: RCT Outcomes: Bed falls, staff attitudes toward the use of the system | Setting: Geriatric evaluation and treatment unit Population: 70 patients (86 percent female), avg. age 84 years, at risk for falls | Bed alarm system | Falls: Bed alarms reduced falls by 68 percent, but this was not statistically significant (odds ratio = 0.32; 95% CI = 0.10–1.03). The bed alarm system was well accepted by patients, families, and nurses.
Mayo 1994^155^ | Environmental interventions for fall prevention in acute and long-term care | RCT | Design: Blinded RCT Outcomes: Fall rates | Setting: Geriatric care unit at university hospital Population: 70 patients at risk for falls | Identification bracelet for patients at high risk for falls | Falls: Identification bracelets increase fall risk in high-risk patients (hazard ratio = 1.3, 95% CI = 0.8–2.4), but this was not statistically significant.
Kelly 2002^240^ | Environmental interventions for fall prevention in acute and long-term care | Pretest and post-test study | Design: Crossover design for 1 week Outcomes: Fall rates | Setting: Medicare unit of a skilled nursing facility Population: 47 patients at high risk for falls | Movement detection patch attached to the thigh | Falls: Fall rates decreased from 4.0 falls per 100 patient days to 3.4 falls per 100 days for patients with movement detection patches.
Kwok 2006^222^ | Environmental interventions for fall prevention in acute and long-term care | RCT | Design: RCT Outcomes: Physical restraints use, fall rates | Setting: Two geriatric stroke rehabilitation wards in a convalescent hospital in Hong Kong Population: 180 geriatric patients perceived by nurses to be at risk of falls | Bed-chair pressure sensor or control | Falls: No difference in fall rates between chair alarm group and control group. Restraints: No difference in physical restraint use between chair alarm group and control group.

†† Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 7

Studies Examining Physical Activity Interventions in Acute and Long-Term Care (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^‡‡^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Mulrow 1994^241^ | Physical activity interventions for fall prevention in acute and long-term care | RCT | Design: RCT Outcomes: Fall rates | Setting: 1academic nursing home and 8 community nursing homes Population: 194 frail long-term care residents | Individually tailored one-on-one physical therapy sessions or Friendly visits | Falls: Fall rates increased in the intervention group (79 versus 60; P = 0.11).
Nowalk 2001^244^ | Physical activity interventions for fall prevention in acute and long-term care | RCT | Design: RCT Outcomes: Fall rates | Setting: 2 long-term care facilities Population: 110 elderly men and women (avg. age 84), capable of ambulating and able to follow simple directions | Resistance-endurance with enhanced exercise or Tai Chi with enhanced exercise or enhanced exercise | Falls and other outcomes: Time to first fall, time to death, number of days hospitalized, and incidence of falls did not differ among the treatment and control groups (P > 0.05).
Choi 2005^243^ | Physical activity interventions for fall prevention in acute and long-term care | Non-randomized trial | Design: A quasi-experimental design with a nonequivalent control group Outcomes: Fall rates | Setting: Residential care facilities Population: 68 fall-prone older adults, avg. age 77.8 years | 12-week Sun-style Tai Chi exercise program | Falls: 38 percent decrease in falls in the Tai Chi group, but not statistically significant (relative risk = 0.62; 95% CI = 0.32–1.19).

‡‡ Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 8

Studies Examining Multimodal Interventions in Acute and Long-Term Care (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^§§^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Rubenstein 1990^242^ | Multimodal interventions in acute and long-term care | RCT | Design: RCT with 2-year followup Outcomes: Fall rates | Setting: Long-term residential care facility Population: 160 ambulatory subjects (avg. age, 87 years) | Tailored interventions based on fall risk factors | Falls: Patients in the intervention group had 9 percent fewer falls. Fall-related deaths: 17 percent fewer deaths than controls by 2 years, but these trends were not statistically significant.
Bakarich 1997^245^ | Multimodal interventions in acute and long-term care | Pretest, post-test | Design: Pretest, post-test Outcomes: Fall rates | Setting: 450-bed metropolitan teaching hospital Population: 2,023 patients ≥ 70 years | Toileting regimen for at-risk patients (confused and having mobility problems) | Falls: 53 percent less falls during shifts in which the risk assessment and toileting intervention was used.
Lane 1999^262^ | Multimodal interventions in acute and long-term care | Pretest, post-test | Design: Pre-post and comparative, descriptive design Outcomes: Fall rates | Setting: Medical-surgical/critical care unit; large community hospital system Population: 292 older patients | Fall-prevention program | Falls: No decrease in patient fall rate was found between patients who fell before and after implementation of the program.
McMurdo 2000^254^ | Multimodal interventions in acute and long-term care | RCT | Design: RCT Outcomes: Falls and fractures | Setting: Nursing home residents Population: 133 residents ≥ 84 years | Assessment/modification and seated balance exercise training program or reminiscence therapy | Falls: 55 percent reduction in fall rates for group with exercise training, but not statistically significant (odds ratio = 0.45; 95% CI = 0.19–1.14).
Jensen 2002^249^ | Multimodal interventions in acute and long-term care | RCT | Design: cluster RCT Outcomes: Fall rates, time to first fall, fall-related injuries | Setting: 9 residential care facilities located in northern Sweden Population: 439 residential care residents ≥ 65 years | Comprehensive fall risk assessment and tailored interventions | Falls: 51 percent reduction in falls (adjusted odds ratio = 0.49; 95% CI = 0.37–0.65). Injuries: 77 percent reduction in fall-related injuries (adjusted odds ratio = 0.23; 95% CI = 0.06–0.94).
Bischoff 2003^247^ | Multimodal interventions in acute and long-term care | RCT | Design: Double-blind RCT Outcomes: Fall rates | Setting: Long-stay geriatric care Population: 122 elderly women (mean age, 85.3 years; range, 63–99 years) | 1,200 mg calcium plus 800 IU vitamin D daily or 1,200 mg calcium daily | Falls: 49 percent reduction of falls in the group that received calcium plus vitamin D (95% CI = 14–71; P < 0.01).
Hofmann 2003^250^ | Multimodal interventions in acute and long-term care | Pretest, post-test | Design: Pretest, post-test Outcomes: Falls, fall-related fractures | Setting: 120-bed nursing home Population: Frail elderly population | Concurrent: Staff education, exercise, and environmental modifications | Falls: 38 percent reduction in fall rates (P = 0.0003). Injuries: 50 percent reduction in injury rates (P > 0.05).
Semin-Goossens 2003^257^ | Multimodal interventions in acute and long-term care | Pretest, post-test | Design: Pretest, post-test pilot study Outcomes: Fall rates | Setting: Academic medical center, 2 medical-surgical units Population: 2,670 patients | Fall prevention guideline with semistructured interventions | Falls: Fall rates in high-risk neurology and medical patients were not reduced.
Haines 2004^251^ | Multimodal interventions in acute and long-term care | RCT | Design: RCT Outcomes: Fall rates, fall-related injury rates, repeat fallers | Setting: 3 subacute wards in rehabilitation and elder care hospital Population: 626 men and women ages 38 to 99 years (avg. 80 years) | Falls risk alert card, exercise, education program, and hip protectors or usual care | Falls: 22 percent decrease in falls (relative risk = 0.78; 95% CI = 0.56–1.06). Injuries: 28 percent decrease in injuries in the intervention group, but not statistically significant (P = 0.20).
Healey 2004^253^ | Multimodal interventions in acute and long-term care | RCT | Design: Cluster randomized trial Outcomes: Fall rates | Setting: Elder care units and associated community units of a district general hospital in England Population: Patients deemed at high risk for falls received intervention | Preprinted care plan for patients identified as at risk of falling and introduced appropriate remedial measures | Falls: 29 percent decrease in falls in the intervention group (relative risk = 0.71; 95% CI = 0.55–0.90, P = 0.006). Injuries: No reduction in injuries.
Jensen 2004^249^ | Multimodal interventions in acute and long-term care | RCT | Design: Cluster-randomized trial Outcomes: Fall rates | Setting: 9 residential care facilities in Sweden Population: 187 residents at high risk for falling ≥ 65 years | Education, environment, exercise, drug review, postfall assessments, hip protectors | Falls: Intervention had no effect on fall rates.
Kerse 2004^256^ | Multimodal interventions in acute and long-term care | RCT | Design: Cluster RCT Outcomes: Fall rates | Setting: Residential care homes Population: 628 residents | Risk assessment followed by tailored interventions | Falls: 34 percent increase in falls (incident rate ratio = 1.34; 95% CI = 1.06–1.72).
Vassallo 2004^208^ | Multimodal interventions in acute and long-term care | Non-randomized trial | Design: Quasi-experimental Outcomes: Fall rates, injury rates, repeat fall rates | Setting: 3 geriatric wards Population: 825 consecutive geriatric patients | Medication adjustment, environmental assessment, wristbands | Falls:; - 25 percent decrease in falls in the intervention group, but not statistically significant (relative risk = 0.75; 95% CI = 0.53–1.05).; - No reduction in recurrent fallers.; Injuries: No reduction in injuries.
Flicker 2005^248^ | Multimodal interventions in acute and long-term care | RCT | Design: Randomized, placebo-controlled, double-blind trial Outcomes: Falls and fall-related fractures | Setting: Multicenter study in 60 assisted living facilities and 89 nursing homes across AustraliaS Population: 625 residents (avg. age 83 years) with vitamin D deficiency | Vitamin D 10,000 IU once, then 1,000 IU daily plus 600 mg calcium or placebo plus 600 mg calcium | Falls: 27 percent decrease in falls in intervention group (incident rate ratio = 0.73; 95% CI = 0.57–0.95). Injuries: 31 percent decrease in injuries, but not statistically significant (odds ratio = 0.69; 95% CI = 0.40–1.18).
Klay 2005^246^ | Multimodal interventions in acute and long-term care | Pretest, post-test study | Design: Pretest, post-test Outcomes: Urinary tract infections, pressure ulcers, and falls | Setting: Connecticut long-term care center Population: 42 female residents who were incontinent or had urgency related to overactive bladder | Individualized continence program | Falls: 58 percent reduction in falls after treatment with individual continence program.
Fonda 2006^260^ | Multimodal interventions in acute and long-term care | Pretest, post-test study | Design: Pretest, post-test Outcomes: Fall rates, fall-related injuries | Setting: Long-term care setting, Australia Population: All patients admitted to the unit | Multistrategy approach: work practice changes, environmental/equipment changes, staff education | Falls: 19 percent reduction in the number of falls per 1,000 patient days (12.5 v 10.1; P = 0.001). Falls: 77 percent reduction in the number of falls resulting in serious injuries per 1,000 patient days (0.73 v 0.17; P < 0.001).
Schwendimann 2006^261^ | Multimodal interventions in acute and long-term care | | Design: Serial survey design Outcomes: Fall rates, fall-related injuries | Setting: 300-bed urban public hospital Population: Adult patients in internal medicine, geriatrics, and surgery | Interdisciplinary falls-prevention program | Falls: Decrease in fall rates, but not statistically significant (pre-9.0, post-7.8; P = 0.086). Injuries: No change in injury rate.

§§ Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

Evidence Table 9

Studies Examining Interventions to Prevent Injury in Acute and Long-Term Care (listed chronologically)

Source | Safety Issue Related to Clinical Practice | Design Type^***^ | Study Design, Study Outcome Measure(s) | Study Setting & Study Population | Study Intervention | Key Finding(s)
Lauritzen 1993^263^ | Physical interventions to prevent fall-related injuries in acute care | RCT | Design: RCT Outcomes: Hip fractures | Setting: 10 of the 28 wards in a nursing home Population: 665 older patients (67 percent female) | External hip protectors | Fractures: 56 percent decrease in hip fractures for patients wearing hip protectors (relative risk = 0.44; 95% CI = 0.21–0.94).
O'Halloran 2004^264^ | Physical interventions to prevent fall-related injuries in acute care | RCT | Design: Cluster RCT Outcomes: Hip fracture | Setting: 127 nursing and residential homes in Northern Ireland Population: 4,117 elderly residents | Hip protectors, staff education | Fractures: Slight increase in hip fractures in the intervention group (adjusted rate ratio = 1.05; 95% CI = 0.77–1.43).
Ray 2005^266^ | Multimodal interventions to prevent fall-related injuries in acute care | RCT | Design: Cluster RCT Outcomes: Serious fall-related injuries | Setting: 112 long-term care facilities Population: 10,558 residents ≥ 65 years, not bedridden | Staff safety education plan with tailored interventions | Injuries:; - No difference in injury rates (adjusted rate ratio = 0.98; 95% CI = 0.83–1.16).; - 21 percent decrease in injury rates for patients with prior fall in facilities with the best compliance, but not statistically significant (adjusted rate ratio = 0.79; 95% CI = 0.57–1.10).
Sato 2005^136^ | Physiologic interventions to prevent fall-related injuries in acute care | RCT | Design: Double blind RCT Outcomes: Hip fractures | Setting: Stroke unit at hospital in Japan Population: 280 male poststroke patients ≥ 65 years | Risedronate 2.5 mg or placebo | Fractures: 81 percent decrease in hip fractures in risedronate group (relative risk = 0.19, 95% CI = 0.04–0.89).
Sato 2005^137^ | Physiologic interventions to prevent fall-related injuries in acute care | RCT | Design: Double blind RCT Outcomes: Hip fractures | Setting: Stroke unit at hospital in Japan Population: 187 female poststroke patients ≥ 65 years | Risedronate 2.5 mg or placebo | Fractures: 86 percent decrease in hip fractures in the risedronate group, but this was not statistically significant (relative risk = 0.14; 95% CI = 0.02–1.2).

*** Study Design Type: (1) Meta-analysis, (2) Randomized controlled trials, (3) Nonrandomized trials, (4) Cross-sectional studies, (5) Case control studies, (6) Pretest and post-test (before and after) studies, (7) Time series studies, (8) Noncomparative studies, (9) Retrospective cohort studies, (10) Prospective cohort studies, (11) Systematic literature reviews, (12) Literature reviews, nonsystematic/narrative, (13) Quality-improvement projects/research, (14) Changing-practice projects/research, (15) Case series, (16) Consensus reports, (17) Published guidelines, (18) Unpublished research, reviews, etc.

### Falls and Related Injuries in the Acute and Long-Term Care Settings

Fall and related injury prevention is a major focus for both acute and long-term health care organizations. In 2005, the Joint Commission added the requirement for fall risk assessment and periodic reassessment as a National Patient Safety Goal in the acute care setting.54 The goal of this requirement is to ensure that all patients are screened for falls and thus seeks to reduce harm from falls. However, the outcome is unpredictable because fall and injury risk assessment instruments have shown inconsistent reliability and validity A more promising extension of this goal starting in 2006 and continuing forward is the additional requisite of implementing and evaluating a fall-prevention program.146 National compliance with these goals has the potential to significantly impact the problem of falls in the acute care setting. Efforts to enhance quality of care in the long-term care environment via improved reporting have the potential to reduce falls and related injuries in these particularly vulnerable patients; however, the successful implementation of fall-prevention programs will be necessary to improve the problem.

Falls in the acute and long-term care settings have several possible consequences. Recurrent falls have been identified as contributing to increases in the length of stay (LOS) in elderly psychiatric patients.147 However, some research has suggested that LOS itself may be a predictor. A fall may also lead to a poorer quality of life because of fallophobia, a fear of future falls, which may itself contribute to fall risk.148 Injuries occur in between 6 and 44 percent of falls in the acute care setting.20, 21, 23 In the long-term care population, between 9 and 15 percent of falls result in injury, with approximately 4 percent of these falls resulting in fractures.149 Additionally, patients who have underlying disease states are more susceptible to injuries; for example, osteoporosis can increase the risk for fracture, and bleeding disorders can increase the risk for subdural hematomas.150 Moreover, fall-related injuries increase resource utilization: injuries from falls lead to increased LOS and an increased chance of unplanned readmission or of discharge to residential or nursing home care.151 Furthermore, inpatients who have incurred an injury due to a fall have approximately 60 percent higher total charges than those who did not fall or those who fell and did not sustain an injury.152

Evans and colleagues,153 via the Joanna Briggs Institute, performed a systematic review of the evidence up to 1997 for fall and injury prevention in the acute care setting. They examined 200 studies related to identification of predictors, risk assessment instrument development and testing, and fall- and injury-prevention interventions. Of these studies, only two were randomized controlled trials (RCTs). The trial by Tideiksaar and colleagues154 examined the use of bed alarms to notify staff when patients at high risk for falls got out of bed; however, this study had a sample size that was too small to identify an effect from using bed alarms. The other RCT examined the use of colored bracelets to identify patients at high risk for falls. Again, the study results were inconclusive.155 Evans and colleagues concluded that the fall risk assessment instruments available were not generalizable. However, they did not adequately compare the psychometric properties of the instruments in question; rather they evaluated research related to the implementation of such instruments, which was relatively weak up to that time. In addition, Evans and colleagues concluded that individual interventions were not more useful that any of the fall-prevention programs that might be developed at a particular institution for a specific subset of patients. However, recent research has seen a growing number of RCTs, which will facilitate the ability to make stronger practice recommendations for this complex and challenging problem.

For this review, research related to falls and related injuries in the acute and long-term care settings were identified and categorized as follows: risk factor identification, risk assessment instruments, and prevention strategies. Each category of research is discussed below.

#### Acute care and long-term care risk factors

Factors associated with patients at risk of falling in the acute care setting have been explored extensively, particularly over the past two decades.17, 87, 156–160 Evans and colleagues161 conducted a systematic review of research and identified 28 risk factors for falling, including impaired mental status, special toileting needs, impaired physical status, and to some extent age and medications. Oliver and colleagues159 reviewed risk factor and risk assessment literature and identified five risk factors consistent across studies: unsteady gait, increased toileting needs, confusion, sedative-hypnotics, and history of falling. In the long-term care environment, risk factors are largely the same, with the addition of inability to transfer effectively162 and short-term memory loss.163 Although ability to transfer and short-term memory function might be characterized by unsteady gait and confusion, these items are expressly captured via the LTCMDS.

Research has consistently demonstrated that multiple factors are associated with falling in elderly and hospitalized patients and that fall risk increases as the number of factors increases.98, 153, 156–159, 164–166 Although increased age is a strong predictor of falling in the community, increased age has not always been identified as a predictor in the acute care setting. Some studies have found increased age to be a risk factor,17, 165 but others have found that increased age is not a factor in acute care.157, 167, 168 Comorbidities and impaired functional status may be more important predictors of falls and subsequent injury in this setting.150, 157 Recent work by Hendrich169 did not support the association between increasing age (older than 65 years) and increasing risk of falling in the inpatient environment. Instead, Hendrich and colleagues169 found that confusion was the most important risk factor associated with the risk of falling. Nevertheless, age must be considered when discussing injury associated with falls because often with age comes frailty. Several researchers have identified gender as a risk factor, with female gender being a stronger risk factor in the older population170 and male gender a stronger factor in the younger population.167, 169, 171 A recent retrospective analysis by Krauss and colleagues170 found that altered mental status was not a factor in falls, but that patients in academic medical centers were more likely to fall. This research was limited because it did not control for patient acuity or staffing levels.

Harwood and colleagues172, 173 reviewed the literature related to visual problems and falls and found that uncorrected visual impairment nearly doubled the risk of falling. Cardiovascular causes of falls derive predominantly from neurally mediated disorders (e.g., vasovagal syncope) and cardiac abnormalities (e.g., arrhythmias, infarction, valvular stenosis).174, 175 Time of day has also been implicated; Tutuarimia and colleagues176 identified a higher rate of falls on the night shift, but this is inconsistent with other research and may in fact be explained by staffing patterns. Association of falls to the lunar cycle has also been explored, but no association was found.177

Vitamin D deficiency has been implicated as a risk factor for falls and fracture in the long-term care setting.178 In addition, elevated alkaline phosphatase and low serum parathyroid hormone have been identified as predictors for falls,179, 180 and anemia has also been implicated.181

A number of researchers are exploring the relationship between nurse-to-patient staffing ratios and an increase in the incidence of falls.20, 176, 182–184 Some of this work has identified an inverse association between licensed nurse staffing ratios and fall rates (i.e., a higher proportion of nurses is associated with lower fall rates);176, 182, 184, 185 however, the overall the results are inconclusive.186 In addition, a growing body of research related to failure to rescue, defined as being “based on the premise that although deaths in hospitals are sometimes unavoidable, many can be prevented,”187–189 supports the inclusion of unanticipated physiologic events in the definition of falls since the patient’s safety issues should be addressed at all times. Other researchers examining nurse staffing ratios and fall rates suggest that fall rates are reduced by increasing the number of nurse aids rather than licensed nursing staff.190 This is potentially supported by recent work by Krauss and colleagues;191 of the fallers in their case-control study, 85 percent of those in need of assistance or supervision with ambulation fell while not being supervised.

Certain subgroups of patients have been identified at higher risk because of the inherent characteristics of their disease process or treatment modalities. These groups include geriatric, behavioral health, oncology, rehabilitation, stroke, and multiple sclerosis patients. In the behavioral health setting, fall rates range from 4.5 to 25 falls per 1,000 patient days.192, 193 Researchers have identified the typical faller in the behavioral health setting as a female with a history of falls; who was younger than 65 years of age; who was experiencing anxiety and agitation; and who was receiving a sedative, a tranquilizer, or a laxative.194 Irvin195 explored risk factors in the psychiatric setting and found that gait or balance problems and history of falls were the primary predictors. Although many of these characteristics are consistent with patients in the acute care setting, younger age and comorbidities such as depression and psychosis are often predictors in the behavioral health population.196–199 In addition, treatments specific to behavioral health patients are different than those in the acute care setting. For example, patients being treated for late-life depression are at risk for falling in the first weeks of using a tricyclic antidepressant and should be monitored closely while they are adjusting to the new medication.75 De Carle and Kohn200, 201 have described risk factors in behavioral health patients and have identified electroconvulsive therapy as a predictor.

Patients in rehabilitation units are also at higher risk, likely because they have suffered neurological injuries such as stroke or head injury, which precipitate muscle weakness, impaired cognition, and impulsivity.202–205 In addition, these patients are being physically challenged, which places them in higher-risk situations and thus at greater risk for falling.206

In the pediatric inpatient setting, fall rates range from 0 to 0.8 per 1,000 patient days.207 These rates are very low compared to adult inpatient and long-term care rates. The factors that limit the number of falls in this population are unclear, but may be related to increased supervision of pediatric patients via higher nurse-to-patient staffing ratios and the common practice of parents staying with pediatric inpatients.

#### Injury risk factors in the acute and long-term care setting

In general, injury risk factors are similar across care areas. Vassallo and colleagues208 examined the risk factors associated with injury in a group of inpatient fallers and found that three factors were associated with injuries related to falls: (1) history of falls, (2) confusion, and (3) unsafe gait. In addition to these, Rothschild and colleagues134 identified physiological processes, such as increased bleeding tendencies and osteoporosis, as factors that increased risk for bleeding or fracture. The risk for medications or physiologic factors to precipitate injuries related to bleeding have been explored on a limited basis in the inpatient population. Contrary to results in the community,84 Stein and team209 found that hospitalized stroke patients who are anticoagulated are not at higher risk for injury than nonanticoagulated patients; however, this study was small and the issue warrants further research. Bond and colleagues210 examined over a 4-year period the risk for bleeding injury among 1,600 patients who fell while hospitalized. These researchers found that half of the patients were on thrombotic therapy and that the incidence of fall-related intracranial hemorrhage was low, even in persons taking warfarin. The authors suggested that selection bias may be a factor because physicians might withhold anticoagulant therapy for patients who have a higher fall risk. More recently, Spector and colleagues211 performed a large study of nursing homes and found that 85 percent of fractures were caused by falls, and that those with epilepsy, those with agitation, and those taking anticonvulsants had the highest risk of sustaining a fracture if they fell.

Table 2

Risk Factors for Falls and Injuries in Acute and Long-Term Care

Intrinsic Risk Factors | Fall Risk | Injury Risk
Demographics
• Age | Across ages | Older
• Gender | Male | Female
Cognitive Function
• Agitation | Yes | Yes
• Anxiety | Yes | No data
• Cognitive impairment | Yes | No data
• Impulsivity | Yes | No data
• Inability to follow instructions | Yes | No data
• Short-term memory loss | Yes | No data
Physical Function
• Fall history | Yes | Yes
• Fatigue | Yes | No data
• Gait problems | Yes | No data
• Impaired muscle strength | Yes | No data
• Impaired physical functioning | Yes | No data
• Toileting needs increased | Yes | No data
• Postural hypotension | Yes | No data
• Visual impairment | Yes | No data
Physiologic Status
• Alkaline phosphatase level elevated | Yes | No data
• Anemia | Yes | No data
• Parathyroid hormone deficiency | Yes | Yes
• Prolonged bleeding time | No data | Yes
• Vitamin D deficiency | Yes | Yes
Comorbidities
• Alzheimer’s disease | Yes | No data
• Depression | Yes | No data
• Diabetes | Yes | No data
• Comorbidities in general | Yes | No data
• Multiple sclerosis | Yes | No data
• Parkinson disease | Yes | No data
• Stroke | Yes | No data
• Syncope | Yes | No data
Medications
• Anticoagulants | No data | Yes
• Antiepileptics | Yes | No data
• Chemotherapeutics | Yes | No data
• Laxatives | Yes | No data
• Psychotropics | Yes | No data
• Sedatives and hypnotics | Yes | No data
Extrinsic Risk Factors | Fall Risk | Injury Risk
Other Factors
• Staffing | Yes | No data
• Time of day | Yes | No data
• Electroconvulsive therapy (in behavioral health) | Yes | No data
• Being physically challenged (in rehab) | Yes | No data

#### Acute care risk assessment instruments

Many tools have been developed to identify patients at highest risk for falling in the acute care setting.21, 159, 167, 169, 212–215 Perell and colleagues87 reviewed risk assessment tools and identified 6 functional assessment instruments and 15 fall risk assessment instruments developed by nursing. Vassallo and colleagues216 concurrently examined the predictive validity in the acute care setting of four commonly used risk assessment instruments (STRATIFY, Downton, Tullamore, and Tinetti) and found that the STRATIFY instrument was the easiest to use, was most effective of the four at predicting falls in the first week of inpatient admission (total predictive accuracy of 66.6 percent), but had the poorest sensitivity (68.2 percent).

The most commonly reported risk assessment instrument is the Morse Falls Risk Assessment Tool.217 In 2002, O’Connell and Myers218 conducted psychometric testing with this tool on 1,059 patients admitted to an Australian hospital. In this study, the Morse Falls Risk tool had a sensitivity of 83 percent and a specificity of 29 percent, but a positive predictive value of only 18 percent. This resulted in a very high false-positive rate, with the tool identifying more than 70 percent of patients who did not fall at high risk for falling. This research was confounded by the fact that the interventions were applied based on the instrument’s predictions; therefore, the predictive validity cannot be conclusively stated. The STRATIFY Falls Prediction tool also had a low positive predictive value (30 percent) and relatively low sensitivity (66 percent) and specificity (47 percent).212

The Heinrich Falls Risk Model I is reported to be more robust (sensitivity, 77 percent; specificity, 72 percent) than either of the others, and the Hendrich Falls Risk Model II demonstrated even more improvement (sensitivity, 74.9 percent; specificity 73.9, percent; positive predictive value, 75 percent).169 The inclusion of a Get Up and Go test in the Heinrich II tool was the major change between version I and version II. The Get Up and Go test evaluates a person’s ability to rise from a chair in a single movement, which is an assessment method that has been explored in earlier fall-prediction research. It is surprising that the sensitivity and specificity of the tool increases only slightly with the addition of this factor, underscoring the complexity of predicting patient falls. In addition, prospective evaluation of the use of the Hendrich II instrument has yet to be reported.

Several studies have tested the predictive validity of fall risk assessment instruments in relation to the judgment of nurses. Myers and Nikoletti219 concluded that neither the fall risk assessment instrument nor nurses’ clinical judgment acted as a reliable predictor. Eagle and colleagues220 compared the Functional Reach test, the Morse Falls Scale, and nurses’ clinical judgment in the rehabilitation and geriatric environment. This study also concluded that the two standardized assessment processes were no better at predicting falls than the clinical judgment of nurses. A limitation in both of these studies was that the evaluation occurred only at one time point close to admission, which does not account for the variability of patient status throughout a patient’s hospital stay.

In the domain of rehabilitation medicine, Ruchinskas221 compared structured assessments—including the Mini-Mental State Exam, the Geriatric Depression Scale, the Functional Intervention Model, and the clinical judgment of physical and occupational therapists—on admission and discharge. This study concluded that the clinical judgment of therapists had a positive predictive power of 33 percent and a negative predictive power of 82 percent. However, the more accurate predictors of falling for the patients in their sample were a history of falls and presence of a neurological diagnosis. In the residential care environment, Lundin-Olson and colleagues222 found that clinical judgment can contribute to the accurate prediction of fall risk, but is not sufficient on its own as a valid predictor.

Although fall-prediction research has been performed for two decades, it is clear that fall prevention is a complex problem that cannot be solved by risk assessment alone, hence the dissatisfaction with available risk assessment instruments.

#### Long-term care assessment instruments

Lundin-Olson and colleagues223 developed the Mobility Interaction Fall Chart (MIF chart), which is an instrument based on a patients’ ability to walk and talk at the same time, the ability to maintain pace while carrying a glass of water, visual impairment, and difficulty concentrating. When the predictive validity of the MIF chart was evaluated, the researchers found that the chart was helpful only when used in conjunction with clinical judgment and knowledge of a patient’s history of falls, thus making the use of this instrument on its own limited.222

The Downton instrument, originally developed in the community setting, characterizes risk by five factors: (1) increased dependency, (2) cognitive impairment, (3) increased number of physical symptoms, (4) presence of anxiety, and (5) presence of depression.224 This instrument has recently been prospectively evaluated in the long-term care setting with a reported sensitivity ranging from 81 to 95 percent and specificity ranging from 35 to 40 percent.225 Although the specificity is low, this instrument might provide a standardized measure to identify those at risk in the long-term care environment.

Becker and colleagues162 have recently described an algorithm to assess fall risk in the long-term care setting, categorizing long-term care residents into three subgroups: (1) residents requiring assistance to transfer, (2) residents able to transfer with history of falls and requiring the use of restraints, and (3) residents able to transfer and with no history of falls but with urinary incontinence and visual impairment. The researchers found that the residents with the history of falls were at highest risk for falls, which is consistent with other research in this domain, but might be useful to tailor interventions and would warrant prospective evaluation.

#### Acute care pediatric risk assessment instruments

Falls in the acute care pediatric setting are relatively rare; however, standardized assessment may be beneficial to reduce falls and injuries in this population. Graf207 has recently developed an instrument for acute care pediatric risk assessment. According to Graf, factors associated with pediatric falls include (1) seizure medication (odds ratio 4.9), (2) orthopedic diagnosis, (3) not using an IV (odds ratio 3.6), (4) physical/occupational therapy ordered, and (5) LOS (odds ratio 1.84 for every 5 days). This model has a sensitivity and specificity of 69 percent and 84 percent, respectively, and is being prospectively evaluated by the investigator with the hope that standardized assessment will facilitate reduction in these already-low rates.

#### Automated risk assessment in the acute and long-term care settings

Recent national patient safety efforts highlight the promise of using informatics processes to manage patient safety issues such as the management of patient falls. However, to date, most automated risk assessment techniques in the acute care setting are electronic versions of existing fall risk assessment instruments, with limited use of computerized decision support.167, 226, 227 Promising new work in data mining for fall prediction has demonstrated that use of the LTCMDS has the potential to use existing data to generate risk models for patients in this setting. Volrathongchai228 has recently explored the ability to use computerized data mining techniques to identify elderly residents of long-term care facilities who were at risk for falls. Although this work has not been prospectively evaluated, the research found that the use of these data mining techniques, in conjunction with nursing knowledge, had the potential to identify fallers.

#### Acute and long-term care prevention strategies

The goal of any fall- and injury-prevention effort is to decrease adverse outcomes for the patients who are most vulnerable to falling. A beneficial consequence of fall- and related-injury-prevention programs is the potential to streamline resource use, with the added potential for decreased costs associated with this problem.229–231 To date, however, a ubiquitous fall- and injury-prevention strategy has not been identified for hospitalized patients, and implementation of multifaceted strategies is often difficult to introduce in the complex clinical environment.232

Several reviews have examined fall-prevention strategies in the acute and long-term care settings.98, 99, 153, 159, 233 Oliver, Hopper, and Seed234 examined 10 studies, including 3 RCTs and 7 prospective studies with historical controls. Oliver and colleagues found that the pooled effects ratio was 1.0 (95% CI = 0.60–1.68), indicating that overall the interventions were not able to prevent falls. More recently, Oliver and colleagues235 have performed a meta-analysis of fall- and injury-prevention strategies and found a decrease in fall rates with multimodal intervention and a decrease in hip fractures with hip protectors in the long-term care setting. Agostini, Baker, and Bogardus98 conducted a review of the literature related to fall prevention for hospitalized and institutionalized older adults. This review did not pool the results, but examined the literature related to the use of armbands, bed alarms, and restraints for fall prevention, all of which will be discussed individually below.

The use of physical restraints to prevent falls has been refuted because restraints limit mobility, contribute to injuries, and don’t prevent falls.236, 237 Agostini and colleagues98 examined literature related to fall prevention via restraint and side rail use, as well as fall rates when restraints were removed. Six studies found that restraints were associated with increased injuries, and restraint and side rail removal did not increase fall rates. Evans, Wood, and Lambert238 also examined the literature and found 16 studies that examined restraint minimization, concluding that restraint-minimization programs involving effective staff education can reduce injuries and do not increase fall rates.

Several individual fall-prevention interventions have been examined, including the use of armband identification bracelets, exercise regimen, postfall assessment, bed alarms, toileting regimen, and vitamin D supplementation. Mayo and colleagues155 conducted a randomized controlled trial to examine if armbands would help identify high-risk patients in a rehabilitation unit and prevent falls in the high-risk group. The researchers, however, found that high-risk patients with a blue armband had higher fall rates than those without the armband. Despite widespread use, only one study from 1993 has examined bed alarms. Tideiksaar and colleagues154 found that bed alarms were an effective method for fall prevention (relative risk = 0.32), but the intervention warrants further research. An associated intervention, a movement detector, has recently been developed. Kwok and colleagues239 studied movement detectors and found no difference between intervention and control groups. However, a pilot study examined the use of a movement detection patch attached to the thigh, which alerts clinicians when elderly long-term care residents are moving about.240 Kelly and colleagues found a 91 percent decrease in falls during the 1-week testing period. Although this study quality was poor, the intervention might be suitable for select patients and bears further testing. Rask and colleagues224 and Taylor and colleagues225 evaluated the use of a fall-prevention program with a fall coordinator in the long-term care setting; they found that the control nursing homes had increases in fall rates over 4 years, whereas the intervention nursing homes had stable fall rates during the same time period.

Mulrow and colleagues241 examined the effects of a physical therapy exercise intervention for frail long-term care residents and found that fall rates increased in the intervention group. However, the intervention group in this study also showed an increase in general strength and a decrease in the use of assistive devices, making one wonder if the physical therapy intervention sought to decrease the use of assistive devices in inappropriate situations. Rubenstein and colleagues242 examined the ability for post-fall assessment to identify underlying factors that could be remedied to prevent further falls. Choi and colleagues243 examined the effect of Tai Chi in the long-term care setting and found a 38 percent decrease in falls in the Tai Chi group, but this was not statistically significant (relative risk = 0.62; 95% CI = 0.32–1.19). A larger study may demonstrate statistical significance. A more recent study by Nowalk244 reported no difference between groups who received strength training. The authors concluded that long term care residents may require individualized training, rather than group training.

Bakarich, McMillan, and Prosser245 examined the impact of a toileting regimen for elderly confused patients with mobility problems in the acute care units of a large metropolitan teaching hospital. The researchers found that there were 53 percent fewer falls during shifts in which the risk assessment and toileting intervention was used, but that compliance with the assessment and intervention was difficult to maintain. More recently, Klay and Marfyak246 found that a continence specialist in the long-term care environment reduced falls by 58 percent. Vitamin D has also reduced falls in elderly females in the long-term care setting by up to 49 percent, and in both males and females by 25 percent.129, 134, 178, 247, 248 Further investigation of the use of vitamin D in the acute care and rehabilitation setting for fall and injury prevention is warranted. Jensen and colleagues249 examined the effect of exercise training on elderly residential care patients and found an increase in strength and balance, and a nonstatistically significant decrease in falls. This study was limited by its small sample size and unequal distribution of important risk factors such as Mini-Mental State Exam scores across groups.

As with community interventions, tailored, multipronged prevention strategies are being shown to be more effective in acute and long-term care settings than individual interventions alone. Hofmann and colleagues250 used three concurrent interventions—staff education, an exercise program, and environmental modifications—for a frail elderly population. The concurrent use of these interventions decreased the fall rate by 38 percent and decreased the fracture rate by 50 percent. Haines and colleagues251 also examined a multipronged intervention involving staff and patient education, an exercise program, and the use of hip protectors. Researchers found a 22 percent decrease in falls and a 28 percent decrease in injuries in the intervention group.

One of the most promising studies by Jensen and her research team252 investigated the effects of a comprehensive fall risk assessment and tailored intervention program in the long-term care setting. The intervention included assessment via the Mobility Interaction Fall Chart, visual evaluation, medication evaluation, and delirium screening by all members of the care team—physicians, nurses, and physical and occupational therapists. This research demonstrated that the comprehensive assessment and tailored interventions reduced falls by 51 percent and injuries by 77 percent over a 34-week period. Healy and colleagues253 also found a statistically significant reduction in falls (RR = 0.71) by applying a tailored plan of care to adult inpatients who were deemed at high risk for a fall based on having had a previous fall. In effect, this research used history of fall as a method to triage high-risk patients, who then received a comprehensive risk assessment with targeted interventions. This research did not demonstrate a decrease in injuries; however, further research using this technique will be useful. McMurdo, Millar, and Daly254 found up to a 55-percent reduction in fall rates in a group of 133 nursing home residents with comprehensive risk assessment and balance training, but these results were not statistically significant. A larger sample size would provide a better understanding of the effect of the intervention.

Other research examining multimodal interventions have had mixed outcomes. A recent study by Vassallo and colleagues255 in long-term care facilities found a decrease in falls was nullified when the results were controlled for LOS. However, controlling for LOS removes the ability for LOS to be identified as a predictor, which may be the case for patients who stay longer in a hospital setting. Kerse and colleagues256 found that in a group of nursing homes, long-term care residents who were randomized to risk assessment followed by tailored interventions showed an increase in falls (incident rate ratio = 1.34; P = 0.018). Semin-Goossens, van der Helm, and Bossuyt257 evaluated the effect of a guideline with semistructured interventions and found that fall rates in high-risk neurology and medical patients were not reduced. The researchers attributed the failure of the program to resistance by nurses to changing attitudes toward falls with the statement that nurses did not find falls troublesome enough. However, the failure was more likely due to system issues, such as ability to implement and agreement with the guideline, and training issues, which are common with guideline implementation failures.258, 259 In addition, the Semin-Goossens guideline did not use a standardized risk assessment instrument, which might have made it difficult to identify patients at risk. Fonda and colleagues260 studied a multimodal process-improvement plan and found that after 3 years, fall rates were decreased by 19 percent and injuries were decreased by 77 percent. Furthermore, this effect was sustained with continued use of the multimodal intervention. Schwendimann and others261 found a moderate, but not statistically significant decrease in fall rates, and no change in injury rates after implementing an interdisciplinary fall-prevention program. Lane262 found no decrease in patient fall rates before and after implementation of a fall-prevention program. Although the results of multimodal studies are conflicting, it is important to note that none of the studies of multimodal interventions—whether effective or ineffective results—controlled for staffing ratios or skill mix.

An increasing number of studies are examining the prevention of injury in the acute and long-term care settings. Hip protectors have been evaluated in the long-term care environment since the early 1990s. Although early work found that hip protectors were effective in reducing hip fractures in the frail or osteoporitic elderly,263 more recent work indicates that compliance with using hip protectors is difficult to maintain, making recommendation for hip protector use conditional.264, 265 Ray and colleagues266 examined the ability of a 2-day staff safety education plan to reduce serious fall-related injuries and found that this intervention was not effective, but the result may have been confounded by lack of staff compliance with the safety plan. (See Evidence Tables 1 to 9 for individual study results.)

#### Summary of acute and long-term care falls and related injuries

In summary, fall prevention in the acute and long-term care settings is a complex and demanding problem with multiple patient types and risk factors to manage. Standardized risk assessment with multimodal tailored interventions appears to be the most successful method of prevention; however, implementation of comprehensive interventions across care settings can be challenging. Further research toward overcoming barriers to implementation, guideline adherence, staffing ratios, and tailored interventions for newly identified risk factors such as vitamin D deficiency and anemia are warranted. Furthermore, research must be conducted on a larger scale to demonstrate generalizability and to be able to translate evidence into practice.

## Evidence-Based Practice Implications

Screening for fall and injury risk should be performed across settings. In the community, all patients older than 65 years should be screened, and in the home care, acute care, and long-term care settings, patients of all ages should be screened. Screening needs to include injury risk, not just fall risk. The most effective interventions are multimodal ones that address specific areas of risk and work with interdisciplinary fall-prevention teams.

In the community, screening can take place with a general annual physical exam or other routine health care visit. A standardized risk assessment tool should be used, such as the Tinnetti screening tool, which has the highest sensitivity and specificity for use in the community, but screening for injury risk must be included. If a patient is seen in an emergency room because of a fall, evidence suggests that focused fall and injury risk evaluation is warranted, especially if the patient is to be discharged home, i.e., the discharge prescription should include a focused fall risk assessment by the primary care provider or by a fall-prevention clinic. Tailored interventions for elderly community dwellers can decrease fall rates. Interventions that have had the most success in the community include exercise interventions with leg strengthening and balance training (e.g., Tai Chi), medication adjustment, management of cardiac-related syncope, effective diabetes management, management of vitamin D deficiency, and home safety modifications. Interventions to prevent injury in the community include calcium with vitamin D for fracture prevention, and additional fall precautions and increased screening for patients on anticoagulant therapy.

In the acute and long-term care settings, screening should be carried out using a standardized assessment tool for all patients. The Morse tool is the most commonly used in the acute care setting, but it does not screen for injury risk. In the long-term care setting, the LTCMDS may be an effective screening tool. In both acute and long-term care, effective interventions are multimodal and include medication adjustment, environmental adjustment, alarm devices, staff safety education, calcium and vitamin D, exercise interventions, and treatment of other underlying disorders. Interventions to prevent injury in the acute and long-term care settings include limiting restraint use, lowering bedrails, using hip protectors in long-term care, calcium with vitamin D, and possibly bisphosphonates in long-term care. Across the health care continuum, effective interventions have been identified, but their use is not ubiquitous.

## Research Implications

In the community setting, identification of the best timing for screening and reassessment is needed. Identification of methods to build fall- and injury-prevention programs in the community is needed to guide policymakers. In the acute and long-term care settings, large multisite intervention studies that use multimodal interventions tailored for individual risk factors and that control for comorbidities, acuity, staffing, and other environmental factors are needed. Cost-effectiveness studies to characterize the impact of fall- and injury-prevention programs are needed in the acute and long-term care settings.

## Recommendations From Evidence-Based Practice and Research Implications

### 1. Recommendations for screening and assessment

- Fall and injury risk screening should be performed in all settings.
- All patients who fall should receive a comprehensive postfall assessment.
- Methods for computerized screening and followup should be explored.

Table 3

Recommendations for Screening and Assessment

Evidence-Based Practice Recommendations | Research Implications
Community:
- Screen all patients over 65 during routine or other visit.; - For patients who screen positive, refer to fall-injury prevention clinic for focused fall-injury risk assessment, if available.; - Use a standardized risk assessment tool, such as Tinetti’s 9-item screening tool for (1) mobility, (2) morale, (3) mental status, (4) distance vision, (5) hearing, (6) postural blood pressure, (7) back examination, (8) medications, and (9) ability to perform activities of daily living (ADLs).; (Note: This tool does not overtly assess for injury risk.); - For patients > 65 years who present to the emergency department (ED) with a fall, refer to primary care provider for focused fall-injury risk assessment. | - Examine risk factors related to race and gender.; - Identify barriers to widespread screening.; - Examine barriers to establishment of fall-injury prevention clinics.; - Validate risk assessment instruments across culture, race, and language.; - Examine predictive validity of injury risk factors such as antiplatelet therapy, bleeding disorders, vitamin D deficiency, and chronic subdural hematomas.; - evelop instruments for patient self-assessment for fall and injury risk.; - Examine the effect of identification in the ED using large, multicenter randomized controlled trials.; - Identify barriers to widespread adoption.
Evidence-Based Practice Recommendations | Research Implications
Home Care and Long-Term Care:
- Screen patients of all ages.; - Use a standardized risk assessment tool, such as Tinetti’s 9-item screening tool.; - Reassess at regular intervals. | - Validate home care assessment instruments.; - Examine predictive validity of Long Term Care Minimum Data Set.; - Examine best timing for reassessment in home care and long-term care.
Evidence-Based Practice Recommendations | Research Implications
Acute Care Setting:
- Screen patients of all ages.; - Use a standardized risk assessment instrument such as the Morse, Hendrich II, or STRATIFY tools. (Note: These tools do not assess for injury risk.); - Assess for injury risk for patients with injury risk factors such as low BMI, frailty, osteoporosis, vitamin D deficiency, and antiplatelet therapy.; - Reassess patients at regular intervals. | - Develop and validate instruments for subgroups.; - Validate instruments in multiple settings.; - Explore predictive validity of physiologic factors such as low creatinine clearance, vitamin D deficiency, and anemia.; - Validate instruments that assess for injury risk.; - Examine the best timing for reassessment.

### 2. Recommendations for interventions in the community setting

- Apply multimodal interventions as identified by risk assessment.
- Participate in national reporting activities such as ANA–NDNQI.
- Examine the use of computer-based guidelines in all settings.

Table 4

Recommendations for Community Setting

Evidence-Based Practice Recommendations | Research Implications
Fall Prevention:
- Provide balance training with leg strengthening, such as Tai Chi.; - Monitor medication side effects for patients older than 65.; - Limit medications to fewer than four, if possible.; - Monitor and treat calcium and vitamin D deficiency.; - Manage underlying disorders such as cardiac-related syncope, diabetes, and vision problems (e.g., cataracts).; - Provide home safety modifications.; - Educate about use of thin-soled shoes (not running shoes).; - Provide education about how to manage risky situations. | - Examine effect of starting balance training at younger age (i.e., 50 years).; - Examine barriers to establishment and use of balance training centers.; - Identify medications with minimal side effect profiles for patients older than 65.; - Examine medication dosing for groups of medications.; - Examine factors related to calcium and vitamin D metabolism in relation to muscle function.; - Explore factors to manage groups of disorders.; - Explore other diseases that may predict falls.; - Explore barriers to home safety modification.; - Further explore shoe type for specific patient groups.; - Explore fall prevention self-management strategies.
Injury Prevention
- Monitor for calcium and vitamin D deficiency; provide supplements for fracture prevention.; - Increase screening for patients on anticoagulant therapy, those with bleeding disorders, and for the frail and very old.; - Use bisphosphonates for patients with documented osteoporosis. | - Conduct large studies that control for comorbidities, age, and other factors to explore efficacy of hip protectors in the community.; - Identify safety measures for bleeding-injury prevention.; - Explore interventions for the very old and frail.; - Explore safety of long-term use of bisphosphonates.

### 3. Recommendations for interventions i n the acute and long- term care settings

- Apply multimodal interventions as identified by risk assessment.
- Participate in national reporting activities such as ANA–NDNQI.
- Examine the use of computer-based guidelines in all settings.
- Large, multi-site randomized controlled trials that evaluate tailored interventions while controlling for organizational culture, staffing, comorbidities, acuity, and other factors are needed. Injury rates should be the primary outcome of interest, since fall-rate reporting may be an imprecise measure.
- Characterize the cost effectiveness of bundles of tailored interventions.

Table 5

Recommendations for Acute and Long-Term Care

Evidence-Based Practice Recommendations | Research Implications
Fall Prevention
- Educate staff about safety care.; - Train medical team, including students and residents, for fall-injury risk assessment and postfall assessment.; - Use alarm devices.; - Monitor medication side effects and adjust as needed.; - Adjust environment (e.g., design rooms to promote safe patient movement).; - Provide exercise interventions (e.g., Tai Chi) for long- term care patients.; - Provide toileting regimen for confused patients (e.g., check patients every 2 hours).; - Monitor and treat calcium and vitamin D levels for long-term care patients.; - Treat underlying disorders such as syncope, diabetes, and anemia. | - Examine impact of safety education across interdisciplinary team.; - Examine impact of alarms on caregiver satisfaction.; - Examine effect of computerized decision support for medication management.; - Examine cost effectiveness of environmental adjustments.; - Examine usefulness of exercise interventions for acute care patients.; - Study barriers to maintaining and sustaining monitoring activities.; - Examine effects of calcium and vitamin D management for acute care patients.; - Examine constellations of disorders that might precipitate falls.
Injury Prevention
- Limit restraints use.; - Lower bedrails.; - In addition to fall rates, monitor injury rates.; - Use hip protectors for geriatrics and long-term care.; - Use floor mats.; - Monitor prothrombin time, international normalized ration (PT/INR) for patients at risk for falling.; - Ensure postfall assessment.; - Use bisphosphonates for patients with documented osteoporosis. | - Identify methods to overcome barriers to restraints reduction.; - Study efficacy of environmental changes.; - Establish fatal fall rates across settings.; - Identify methods to overcome barriers to use of hip protectors.; - Examine effect of safety flooring.; - Identify safety measures for bleeding-injury prevention.; - Examine barriers to postfall assessment. Explore safety of long-term use of bisphosphonates.

## Conclusion

Falls and related injuries are an important issue across the care continuum. National efforts in the community via Healthy People 2010, in the acute care setting via the Joint Commission’s National Patient Safety Goals, and in the long-term care setting via the Nursing Home Quality Initiative project have the potential to significantly reduce falls and related injuries. The growing number of randomized controlled trials related to fall-prevention efforts is promising. However, most of these studies have been carried out in the community and long-term care environments, with few randomized controlled trials evaluating fall- and injury-prevention measures in the acute care setting. As with other nursing-sensitive quality indicators, recent research demonstrating an association between fall rates and nurse staffing ratios needs to be more fully explored. In addition, further research needs to explore automated methods of assessing and communicating fall risk, better methods for risk identification, and the identification of prevention measures. Indeed, with coordinated efforts to apply the evidence to practice, the problem of falls might be managed more effectively.

## Search Strategy

MEDLINE,^®^ the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^), and Cochrane databases from inception to March 2007 were searched for medical subject heading terms, both individual terms and combinations of the following: accidental falls, patient safety, medical errors, nursing-sensitive quality indicators, and fall prevention. In addition, references from relevant articles were searched using the snowball technique, as were archives of select nursing research and gerontology journals. The Related Links function in MEDLINE was also used to maximize the search strategy. Google, Google Scholar, and citations from identified articles were also searched for additional possible references. Articles related to occupational falls, sports-related falls, alcohol-related falls, and physical abuse-related falls were excluded. Articles that reported physiologic characteristics that are suspected to preclude falls but that did not examine falls or fall-related injuries as outcomes were also excluded because the causative effect on falls and fall-related injuries is, to date, inconclusive. Further, articles that were published in a foreign language were excluded. Two hundred and twenty seven articles were reviewed. Sixty-one of these were intervention research studies related to fall and injury prevention (32 from the community setting; 33 from the acute and long-term care setting).

## References

1 Centers for Disease Control and Prevention. (2006). WISQARS leading causes of nonfatal injury reports.
2 Centers for Disease Control and Prevention. (2006). WISQARS injury mortality reports, 1999 – 2004.
3 Hausdorff JM. (2001). Gait variability and fall risk in community-living older adults: A 1-year prospective study. Arch Phys Med Rehabil.
4 Hornbrook MC, Stevens VJ, Wingfield DJ, et al. (1994). Preventing falls among community-dwelling older persons: Results from a randomized trial. Gerontologist.
5 Lauritzen JB. (1996). Hip fractures: Incidence, risk factors, energy absorption, and prevention. Bone.
6 Office of Statistics and Programming, National Center for Injury Prevention and Control. Wisqars injury mortality reports, 1999 – 2002.
7 (2003). Morbidity and Mortality Weekly Report. Public health and aging: Trends in aging --- United States and worldwide.
8 U.S. Department of Health and Human Services. (2000). Healthy people 2010 - with understanding and improving health and objectives for improving health.
9 Mahoney JE, Palta M, Johnson J, et al. (2000). Temporal association between hospitalization and rate of falls after discharge. Arch Intern Med.
10 Stevens JA, Corso PS, Finkelstein EA, et al. (2006). The costs of fatal and non-fatal falls among older adults. Inj Prev 2006.
11 Shekelle P, Maglione M, Chang J, et al. (2003). Falls prevention interventions in the medicare population.
12 Grubel F. (1959). Falls: A principal patient incident. Hosp Manage.
13 Thurston G. (1957). Fatal hospital falls. BMJ.
14 Halfon P, Eggli Y, Van Melle G, et al. (2001). Risk of falls for hospitalized patients: A predictive model based on routinely available data. J Clin Epidemiol.
15 Vagnair A. (2000). [Preventing falls of patients in the hospital. Toward a comprehensive intervention program]. Krankenpfl Soins Infirm.
16 Leape LL, Brennan TA, Laird N, et al. (1991). The nature of adverse events in hospitalized patients. Results of the harvard medical practice study ii. N Engl J Med.
17 Mahoney JE. (1998). Immobility and falls. Clin Geriatr Med.
18 Morgan VR, Mathison JH, Rice JC, et al. (1985). Hospital falls: A persistent problem. Am J Public Health.
19 Healthcare Cost and Utilization Project. National and regional estimates on hospital use for all patients from the hcup nationwide inpatient sample (nis).
20 Hitcho EB, Krauss MJ, Birge S, et al. (2004). Characteristics and circumstances of falls in a hospital setting: A prospective analysis. J Gen Intern Med.
21 Morse JM. (1997). Preventing patient falls.
22 Resnick B. (2003). Preventing falls in acute care Geriatric nursing protocols.
23 Rohde JM, Myers AH, Vlahov D. (1990). Variation in risk for falls by clinical department: Implications for prevention. Infect Control Hosp Epidemiol.
24 Kiely DK, Kiel DP, Burrows AB, et al. (1998). Identifying nursing home residents at risk for falling. J Am Geriatr Soc.
25 Thapa PB, Brockman KG, Gideon P, et al. (1996). Injurious falls in nonambulatory nursing home residents: A comparative study of circumstances, incidence, and risk factors. J Am Geriatr Soc.
26 Vu MQ, Weintraub N, Rubenstein LZ. (2004). Falls in the nursing home: Are they preventable?. J Am Med Dir Assoc.
27 Rubenstein LZ, Josephson KR, Robbins AS. (1994). Falls in the nursing home. Ann Intern Med.
28 Centers for Disease Control and Prevention. (2006). National nursing home survey 2004.
29 American Nurses Association. Nursing-sensitive quality indicators for acute care settings and ana's safety & quality initiative.
30 National Quality Forum. (2003). National voluntary consensus standards for hospital care: An initial performance measure set.
31 National Quality Forum. (2007). Nqf-endorsed hospital consensus standards.
32 National Quality Forum. (2007). Nqf candidate ambulatory care consensus standards.
33 Maryland Quality Indicator Project. Maryland quality indicator project.
34 Centers for Medicare and Medicaid Services. (2005). Nursing home quality initiative overview.
35 Hirdes JP, Fries BE, Morris JN, et al. (2004). Home care quality indicators (hcqis) based on the mds-hc. Gerontologist.
36 Rollow W, Lied TR, McGann PE, et al. (2006). Assessment of the medicare quality improvement organization program. Ann Intern Med.
37 Centers for Medicare and Medicaid Services. (2003). Minimum data set (mds): Draft version 3.0 for nursing home resident assessment and care screening.
38 Hill-Westmoreland EE, Gruber-Baldini AL. (2005). Falls documentation in nursing homes: Agreement between the minimum data set and chart abstractions of medical and nursing documentation. J Am Geriatr Soc.
39 Levine RS, Briggs NC, Husaini BA, et al. (2005). Hedis prevention performance indicators, prevention quality assessment and healthy people 2010. J Health Care Poor Underserved.
40 (2004). Ahrq quality indicators—guide to prevention quality indicators: Hospital admission for ambulatory care sensitive conditions (revision 4).
41 National Committee for Quality Assurance. (2007). The health plan employer data and information set (hedis®).
42 Close J, Ellis M, Hooper R, et al. (1999). Prevention of falls in the elderly trial (profet): A randomised controlled trial. Lancet.
43 Masud T, Morris RO. (2001). Epidemiology of falls. Age Ageing.
44 Tinetti ME, Speechley M, Ginter SF. (1988). Risk factors for falls among elderly persons living in the community. N Engl J Med.
45 Agostini JV, Baker DI, Bogardus ST. (2001). Prevention of falls in hospitalized and institutionalized older people.
46 Nevitt MC, Cummings SR, Hudes ES. (1991). Risk factors for injurious falls: A prospective study. J Gerontol.
47 American Nurses Association. National database for nursing quality indicators: Guidelines for data collection and submission on quarterly indicators, version 5.0 2005
48 National Center for Health Statistics. International classification of diseases, ninth revision, clinical modification, sixth edition. ICD9-CM - revised as of December 1, 2005.
49 Kumar NP, Thomas A, Mudd P, et al. (2003). The usefulness of carotid sinus massage in different patient groups. Age Ageing.
50 Richardson DA, Bexton R, Shaw FE, et al. (2000). Complications of carotid sinus massage--a prospective series of older patients. Age Ageing.
51 Richardson DR, Hicks MJ, Walker RB. (2002). Falls in rural elders: An empirical study of risk factors. J Am Board Fam Pract.
52 Committee on Data Standards for Patient Safety. (2003). Patient safety: Achieving a new standard for care.
53 Committee on Quality of Health Care in America. (1999). To err is human: Building a safer health system.
54 Joint Commission on the Accreditation of Hospitals. 2005 hospitals' national patient safety goals.
55 Wallace C, Reiber GE, LeMaster J, et al. (2002). Incidence of falls, risk factors for falls, and fall-related fractures in individuals with diabetes and a prior foot ulcer. Diabetes Care.
56 Mackintosh SF, Goldie P, Hill K. (2005). Falls incidence and factors associated with falling in older, community-dwelling, chronic stroke survivors (> 1 year after stroke) and matched controls. Aging Clin Exp Res.
57 Rubenstein LZ, Josephson KR. (2002). The epidemiology of falls and syncope. Clin Geriatr Med.
58 Dharmarajan TS, Norkus EP. (2004). Mild anemia and the risk of falls in older adults from nursing homes and the community. J Am Med Dir Assoc.
59 Dharmarajan TS, Avula S, Norkus EP. (2007). Anemia increases risk for falls in hospitalized older adults: An evaluation of falls in 362 hospitalized, ambulatory, long-term care, and community patients. J Am Med Dir Assoc.
60 Bassiony MM, Rosenblatt A, Baker A, et al. (2004). Falls and age in patients with alzheimer's disease. J Nerv Ment Dis.
61 Fink HA, Kuskowski MA, Orwoll ES, et al. (2005). Association between parkinson's disease and low bone density and falls in older men: The osteoporotic fractures in men study. J Am Geriatr Soc.
62 Dharmarajan TS, Akula M, Kuppachi S, et al. (2005). Vitamin d deficiency in community older adults with falls of gait imbalance: An under-recognized problem in the inner city. J Nutr Elder.
63 Dhesi JK, Jackson SH, Bearne LM, et al. (2004). Vitamin d supplementation improves neuromuscular function in older people who fall. Age Ageing.
64 Dukas LC, Schacht E, Mazor Z, et al. (2005). A new significant and independent risk factor for falls in elderly men and women: A low creatinine clearance of less than 65 ml/min. Osteoporos Int.
65 Watanabe Y. (2005). Fear of falling among stroke survivors after discharge from inpatient rehabilitation. Int J Rehabil Res.
66 Wilson MM, Miller DK, Andresen EM, et al. (2005). Fear of falling and related activity restriction among middle-aged african americans. J Gerontol A Biol Sci Med Sci.
67 Gerdhem P, Ringsberg KA, Akesson K, et al. (2005). Clinical history and biologic age predicted falls better than objective functional tests. J Clin Epidemiol.
68 Delbaere K, Crombez G, Vanderstraeten G, et al. (2004). Fear-related avoidance of activities, falls and physical frailty. A prospective community-based cohort study. Age Ageing.
69 Speciale S, Turco R, Magnifico F, et al. (2004). Frailty is the main predictor of falls in elderly patients undergoing rehabilitation training. Age Ageing.
70 Chan BK, Marshall LM, Winters KM, et al. (2007). Incident fall risk and physical activity and physical performance among older men: The osteoporotic fractures in men study. Am J Epidemiol.
71 Reuben DB, Frank JC, Hirsch SH, et al. (1999). A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc.
72 Clemson L, Cumming RG, Heard R. (2003). The development of an assessment to evaluate behavioral factors associated with falling. Am J Occup Ther.
73 Sherrington C, Menz HB. (2003). An evaluation of footwear worn at the time of fall-related hip fracture. Age Ageing.
74 Gavin-Dreschnack D, Nelson A, Fitzgerald S, et al. (2005). Wheelchair-related falls: Current evidence and directions for improved quality care. J Nurs Care Qual.
75 Joo JH, Lenze EJ, Mulsant BH, et al. (2002). Risk factors for falls during treatment of late-life depression. J Clin Psychiatry.
76 Landi F, Onder G, Cesari M, et al. (2005). Psychotropic medications and risk for falls among community-dwelling frail older people: An observational study. J Gerontol A Biol Sci Med Sci.
77 Morbidity and Mortality Weekly Report. Annual rate of nonfatal, medically attended fall injuries among adults aged >65 years—United States, 2001–2003, 2006.
78 Reyes-Ortiz CA, Al Snih S, Loera J, et al. (2004). Risk factors for falling in older mexican americans. Ethn Dis.
79 Hanlon JT, Landerman LR, Fillenbaum GG, et al. (2002). Falls in african american and white community-dwelling elderly residents. J Gerontol A Biol Sci Med Sci.
80 Faulkner KA, Cauley JA, Zmuda JM, et al. (2005). Ethnic differences in the frequency and circumstances of falling in older community-dwelling women. J Am Geriatr Soc.
81 Porthouse J, Birks YF, Torgerson DJ, et al. (2004). Risk factors for fracture in a uk population: A prospective cohort study. QJM.
82 Porthouse J, Cockayne S, King C, et al. (2005). Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin d3) for prevention of fractures in primary care. BMJ.
83 Colon-Emeric CS, Pieper CF, Artz MB. (2002). Can historical and functional risk factors be used to predict fractures in community-dwelling older adults? Development and validation of a clinical tool. Osteoporos Int.
84 Ohm C, Mina A, Howells G, et al. (2005). Effects of antiplatelet agents on outcomes for elderly patients with traumatic intracranial hemorrhage. J Trauma.
85 Baechli H, Nordmann A, Bucher HC, et al. (2004). Demographics and prevalent risk factors of chronic subdural haematoma: Results of a large single-center cohort study. Neurosurg Rev.
86 Tinetti ME. (1986). Performance-oriented assessment of mobility problems in elderly patients. J Am Geriatr Soc.
87 Perell KL, Nelson A, Goldman RL, et al. (2001). Fall risk assessment measures: An analytic review. J Gerontol A Biol Sci Med Sci.
88 Lord SR, Tiedemann A, Chapman K, et al. (2005). The effect of an individualized fall prevention program on fall risk and falls in older people: A randomized, controlled trial. J Am Geriatr Soc.
89 Scott V, Votova K, Scanlan A, et al. (2007). Multifactorial and functional mobility assessment tools for fall risk among older adults in community, home-support, long-term and acute care settings. Age Ageing.
90 Davison J, Bond J, Dawson P, et al. (2005). Patients with recurrent falls attending accident & emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing.
91 Lee JS, Hurley MJ, Carew D, et al. (2007). A randomized clinical trial to assess the impact on an emergency response system on anxiety and health care use among older emergency patients after a fall. Acad Emerg Med.
92 Miller DK, Lewis LM, Nork MJ, et al. (1996). Controlled trial of a geriatric case-finding and liaison service in an emergency department. J Am Geriatr Soc.
93 Weigand JV, Gerson LW. (2001). Preventive care in the emergency department: Should emergency departments institute a falls prevention program for elder patients? A systematic review. Acad Emerg Med.
94 Whitehead C, Wundke R, Crotty M, et al. (2003). Evidence-based clinical practice in falls prevention: A randomised controlled trial of a falls prevention service. Aust Health Rev.
95 Liaw ST, Sulaiman N, Pearce C, et al. (2003). Falls prevention within the australian general practice data model: Methodology, information model, and terminology issues. J Am Med Inform Assoc.
96 Lord SR, Menz HB, Tiedemann A. (2003). A physiological profile approach to falls risk assessment and prevention. Phys Ther.
97 Dyer CA, Watkins CL, Gould C, et al. (1998). Risk-factor assessment for falls: From a written checklist to the penless clinic. Age Ageing.
98 Agostini JV, Baker DI, Bogardus ST. (2001). Prevention of falls in hospitalized and institutionalized older people.
99 Chang JT, Morton SC, Rubenstein LZ, et al. (2004). Interventions for the prevention of falls in older adults: Systematic review and meta-analysis of randomised clinical trials. BMJ.
100 Cumming RG. (2002). Intervention strategies and risk-factor modification for falls prevention. A review of recent intervention studies. Clin Geriatr Med.
101 Gillespie LD. (2004). Preventing falls in elderly people. BMJ.
102 Gillespie LD, Gillespie WJ, Cumming R, et al. Interventions for preventing falls in the elderly. Cochrane Database Syst Rev.
103 Gillespie LD, Gillespie WJ, Robertson MC, et al. Interventions for preventing falls in elderly people. Cochrane Database Syst Rev.
104 Gillespie LD, Gillespie WJ, Robertson MC, et al. Interventions for preventing falls in elderly people. Cochrane Database Syst Rev.
105 Gillespie LD, Gillespie WJ, Robertson MC, et al. (2004). Interventions for prevening falls in elderly people. Cochrane Database Syst Rev [Systematic Review].
106 Province MA, Hadley EC, Hornbrook MC, et al. (1995). The effects of exercise on falls in elderly patients. A preplanned meta-analysis of the ficsit trials. Frailty and injuries: Cooperative studies of intervention techniques. JAMA.
107 Avenell A, Gillespie WJ, Gillespie LD, et al. Vitamin d and vitamin d analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev.
108 Nitz JC, Choy NL. (2004). The efficacy of a specific balance-strategy training programme for preventing falls among older people: A pilot randomised controlled trial. Age Ageing.
109 Perell KL, Manzano ML, Weaver R, et al. (2006). Outcomes of a consult fall prevention screening clinic. Am J Phys Med Rehabil.
110 Lightbody E, Watkins C, Leathley M, et al. (2002). Evaluation of a nurse-led falls prevention programme versus usual care: A randomized controlled trial. Age Ageing.
111 Hogan DB, MacDonald FA, Betts J, et al. (2001). A randomized controlled trial of a community-based consultation service to prevent falls. CMAJ.
112 Li F, Harmer P, Fisher KJ, et al. (2005). Tai chi and fall reductions in older adults: A randomized controlled trial. J Gerontol A Biol Sci Med Sci.
113 Barnett A, Smith B, Lord SR, et al. (2003). Community-based group exercise improves balance and reduces falls in at-risk older people: A randomised controlled trial. Age Ageing.
114 Clemson L, Cumming RG, Kendig H, et al. (2004). The effectiveness of a community-based program for reducing the incidence of falls in the elderly. A randomized trial.
115 Province MA, Hadley EC, Hornbrook MC, et al. (1995). The effects of exercise on falls in elderly patients. A preplanned meta-analysis of the ficsit trials. Frailty and injuries: Cooperative studies of intervention techniques. Jama.
116 Rubenstein LZ, Josephson KR, Trueblood PR, et al. (2000). Effects of a group exercise program on strength, mobility, and falls among fall-prone elderly men. J Gerontol A Biol Sci Med Sci.
117 Sattin RW, Easley KA, Wolf SL, et al. (2005). Reduction in fear of falling through intense tai chi exercise training in older, transitionally frail adults. J Am Geriatr Soc.
118 Suzuki T, Kim H, Yoshida H, et al. (2004). Randomized controlled trial of exercise intervention for the prevention of falls in community-dwelling elderly japanese women. J Bone Miner Metab.
119 Wayne PM, Scarborough DM, Krebs DE, et al. (2005). Tai chi for vestibulopathic balance dysfunction: A case study. Altern Ther Health Med.
120 Wolf SL, Barnhart HX, Ellison GL, et al. (1997). The effect of tai chi quan and computerized balance training on postural stability in older subjects. Atlanta ficsit group. Frailty and injuries: Cooperative studies on intervention techniques. Phys Ther.
121 Wolf SL, Barnhart HX, Kutner NG, et al. (2003). Selected as the best paper in the 1990s: Reducing frailty and falls in older persons: An investigation of tai chi and computerized balance training. J Am Geriatr Soc.
122 Wolf SL, Sattin RW, Kutner M, et al. (2003). Intense tai chi exercise training and fall occurrences in older, transitionally frail adults: A randomized, controlled trial. J Am Geriatr Soc.
123 Robertson MC, Campbell AJ, Gardner MM, et al. (2002). Preventing injuries in older people by preventing falls: A meta-analysis of individual-level data. J Am Geriatr Soc.
124 Reinsch S, MacRae P, Lachenbruch PA, et al. (1992). Attempts to prevent falls and injury: A prospective community study. Gerontologist.
125 Faber MJ, Bosscher RJ, Chin A, Paw MJ, et al. (2006). Effects of exercise programs on falls and mobility in frail and pre-frail older adults: A multicenter randomized controlled trial. Arch Phys Med Rehabil.
126 Lin MR, Hwang HF, Wang YW, et al. (2006). Community-based tai chi and its effect on injurious falls, balance, gait, and fear of falling in older people. Phys Ther.
127 Luukinen H, Lehtola S, Jokelainen J, et al. (2007). Pragmatic exercise-oriented prevention of falls among the elderly: A population-based, randomized, controlled trial. Prev Med.
128 Nieves JW. (2005). Osteoporosis: The role of micronutrients. Am J Clin Nutr.
129 Bischoff-Ferrari HA, Willett WC, Wong JB, et al. (2005). Fracture prevention with vitamin d supplementation: A meta-analysis of randomized controlled trials. JAMA.
130 Grant AM, Avenell A, Campbell MK, et al. (2005). Oral vitamin d3 and calcium for secondary prevention of low-trauma fractures in elderly people (randomised evaluation of calcium or vitamin d, record): A randomised placebo-controlled trial. Lancet.
131 Mosekilde L. (2005). Vitamin d and the elderly. Clin Endocrinol (Oxf).
132 Latham NK, Anderson CS, Lee A, et al. (2003). A randomized, controlled trial of quadriceps resistance exercise and vitamin d in frail older people: The frailty interventions trial in elderly subjects (fitness). J Am Geriatr Soc.
133 Latham NK, Anderson CS, Reid IR. (2003). Effects of vitamin d supplementation on strength, physical performance, and falls in older persons: A systematic review. J Am Geriatr Soc.
134 Bischoff-Ferrari HA, Orav EJ, Dawson-Hughes B. (2006). Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: A 3-year randomized controlled trial. Arch Intern Med.
135 Stevenson M, Jones ML, De Nigris E, et al. (2005). A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess.
136 Sato Y, Iwamoto J, Kanoko T, et al. (2005). Risedronate sodium therapy for prevention of hip fracture in men 65 years or older after stroke. Arch Intern Med.
137 Sato Y, Kanoko T, Satoh K, et al. (2005). The prevention of hip fracture with risedronate and ergocalciferol plus calcium supplementation in elderly women with alzheimer disease: A randomized controlled trial. Arch Intern Med.
138 McCloskey EV, Beneton M, Charlesworth D, et al. (2007). Clodronate reduces the incidence of fractures in community-dwelling elderly women unselected for osteoporosis: Results of a double-blind, placebo-controlled randomized study. J Bone Miner Res.
139 Clemson L, Cumming RG, Roland M. (1996). Case-control study of hazards in the home and risk of falls and hip fractures. Age Ageing.
140 Morgan RO, Virnig BA, Duque M, et al. (2004). Low-intensity exercise and reduction of the risk for falls among at-risk elders. J Gerontol A Biol Sci Med Sci.
141 Nikolaus T, Bach M. (2003). Preventing falls in community-dwelling frail older people using a home intervention team (hit): Results from the randomized falls-hit trial. J Am Geriatr Soc.
142 Rodriguez JG, Baughman AL, Sattin RW, et al. (1995). A standardized instrument to assess hazards for falls in the home of older persons. Accid Anal Prev.
143 Steinberg M, Cartwright C, Peel N, et al. (2000). A sustainable programme to prevent falls and near falls in community dwelling older people: Results of a randomised trial. J Epidemiol Community Health.
144 Robbins S, Gouw GJ, McClaran J. (1992). Shoe sole thickness and hardness influence balance in older men. J Am Geriatr Soc.
145 Kenny RA, O'Shea D, Walker HF. (2002). Impact of a dedicated syncope and falls facility for older adults on emergency beds. Age Ageing.
146 Joint Commission on the Accreditation of Hospitals. (2005). 2006 critical access hospital and hospital national patient safety goals.
147 Greene E, Cunningham CJ, Eustace A, et al. (2001). Recurrent falls are associated with increased length of stay in elderly psychiatric inpatients. Int J Geriatr Psychiatry.
148 Parry SW, Steen N, Galloway SR, et al. (2001). Falls and confidence related quality of life outcome measures in an older british cohort. Postgrad Med J.
149 Francis RM. (2001). Falls and fractures. Age Ageing.
150 Rothschild JM, Bates DW, Leape LL. (2000). Preventable medical injuries in older patients. Arch Intern Med.
151 Frels C, Williams P, Narayanan S, et al. (2002). Iatrogenic causes of falls in hospitalised elderly patients: A case-control study. Postgrad Med J.
152 Bates DW, Pruess K, Souney P, et al. (1995). Serious falls in hospitalized patients: Correlates and resource utilization. Am J Med.
153 Evans D, Hodgkinson B, Lambert L, et al. (1998). Falls in acute hospitals - a systematic review: Joanna Briggs Center for Evidence Based Nursing and MidWifery.
154 Tideiksaar R, Feiner CF, Maby J. (1993). Falls prevention: The efficacy of a bed alarm system in an acute-care setting. Mt Sinai J Med.
155 Mayo NE, Gloutney L, Levy AR. (1994). A randomized trial of identification bracelets to prevent falls among patients in a rehabilitation hospital. Arch Phys Med Rehabil.
156 Morse JM. (1985). A retrospective analysis of patient falls. Can J Public Health.
157 Morse JM. (1985). Morse fall scale.
158 Morse JM, Tylko SJ, Dixon HA. (1987). Characteristics of the fall-prone patient. Gerontologist.
159 Oliver D, Daly F, Martin FC, et al. (2004). Risk factors and risk assessment tools for falls in hospital in-patients: A systematic review. Age Ageing.
160 Passaro A, Volpato S, Romagnoni F, et al. (2000). Benzodiazepines with different half-life and falling in a hospitalized population: The gifa study. Gruppo italiano di farmacovigilanza nell'anziano. J Clin Epidemiol.
161 Evans D, Hodgkinson B, Lambert L, et al. (2001). Falls risk factors in the hospital setting: A systematic review. Int J Nurs Pract.
162 Becker C, Loy S, Sander S, et al. (2005). An algorithm to screen long-term care residents at risk for accidental falls. Aging Clin Exp Res.
163 Kron M, Loy S, Sturm E, et al. (2003). Risk indicators for falls in institutionalized frail elderly. Am J Epidemiol.
164 Morse JM. (1998). Predicting fall risk. Can J Nurs Res.
165 Rubenstein LZ, Powers CM, MacLean CH. (2001). Quality indicators for the management and prevention of falls and mobility problems in vulnerable elders. Ann Intern Med.
166 Tinetti ME, Williams CS. (1997). Falls, injuries due to falls, and the risk of admission to a nursing home. N Engl J Med.
167 Currie LM, Mellino LV, Cimino JJ, et al. (2004). Development and representation of a fall-injury risk assessment instrument in a clinical information system. Medinfo.
168 Hendrich AL. Preventing falls.
169 Hendrich AL, Bender PS, Nyhuis A. (2003). Validation of the hendrich ii fall risk model: A large concurrent case/control study of hospitalized patients. Appl Nurs Res.
170 Krauss MJ, Nguyen SL, Dunagan WC, et al. (2007). Circumstances of patient falls and injuries in 9 hospitals in a midwestern healthcare system. Infect Control Hosp Epidemiol.
171 Groves JE, Lavori PW, Rosenbaum JF. (1993). Accidental injuries of hospitalized patients. A prospective cohort study. Int J Technol Assess Health Care.
172 Harwood RH. (2001). Visual problems and falls. Age Ageing.
173 Harwood RH, Foss AJ, Osborn F, et al. (2005). Falls and health status in elderly women following first eye cataract surgery: A randomised controlled trial. Br J Ophthalmol.
174 Carey BJ, Potter JF. (2001). Cardiovascular causes of falls. Age Ageing.
175 Eltrafi A, King D, Silas JH, et al. (2000). Role of carotid sinus syndrome and neurocardiogenic syncope in recurrent syncope and falls in patients referred to an outpatient clinic in a district general hospital. Postgrad Med J.
176 Tutuarima JA, de Haan RJ, Limburg M. (1993). Number of nursing staff and falls: A case-control study on falls by stroke patients in acute-care settings. J Adv Nurs.
177 Schwendimann R, Joos F, Geest SD, et al. (2005). Are patient falls in the hospital associated with lunar cycles? A retrospective observational study. BMC Nursing.
178 Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. (2004). Effect of vitamin d on falls: A meta-analysis. JAMA.
179 O'Hagan C, O'Connell B. (2005). The relationship between patient blood pathology values and patient falls in an acute-care setting: A retrospective analysis. Int J Nurs Pract.
180 Sambrook PN, Chen JS, March LM, et al. (2004). Serum parathyroid hormone predicts time to fall independent of vitamin d status in a frail elderly population. J Clin Endocrinol Metab.
181 Dharmarajan TS, Avula S, Norkus EP. (2006). Anemia increases risk for falls in hospitalized older adults: An evaluation of falls in 362 hospitalized, ambulatory, long-term care, and community patients. Journal of the American Medical Directors Association.
182 Dunton N, Gajewski B, Taunton RL, et al. (2004). Nurse staffing and patient falls on acute care hospital units. Nurs Outlook.
183 McGillis Hall L, Doran D, Pink GH. (2004). Nurse staffing models, nursing hours, and patient safety outcomes. J Nurs Adm.
184 Whitman GR, Kim Y, Davidson LJ, et al. (2002). The impact of staffing on patient outcomes across specialty units. J Nurs Adm.
185 Loan LA, Jennings BM, Brosch LR, et al. (2003). Indicators of nursing care quality. Findings from a pilot study. Outcomes Manag.
186 Lake ET, Cheung RB. (2006). Are patient falls and pressure ulcers sensitive to nurse staffing?. West J Nurs Res.
187 Aiken LH, Clarke SP, Sloane DM, et al. (2002). Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA.
188 Clarke SP, Aiken LH. (2003). Failure to rescue: Needless deaths are prime examples of the need for more nurses at the bedside. AJN.
189 Needleman J, Buerhaus P, Mattke S, et al. (2002). Nurse-staffing levels and the quality of care in hospitals. N Engl J Med.
190 Unruh L. (2003). Licensed nurse staffing and adverse events in hospitals. Med Care.
191 Krauss MJ, Evanoff B, Hitcho EB, et al. (2005). A case-control study of patient, medication, and care-related risk factors for inpatient falls. J Gen Intern Med.
192 Draper B, Busetto G, Cullen B. (2004). Risk factors for and prediction of falls in an acute aged care psychiatry unit. Australasian Journal of Ageing.
193 Mahoney JE. (1998). Immobility and falls. Clin Geriatr Med.
194 Vaughn K, Young BC, Rice F, et al. (1993). A retrospective study of patient falls in a psychiatric hospital. J Psychosoc Nurs Ment Health Serv.
195 Irvin DJ. (1999). Psychiatric unit fall event. J Psychosoc Nurs Ment Health Serv.
196 Kim KD, Ng KC, Ng SK, et al. (2001). Falls amongst institutionalized psycho-geriatric patients. Singapore Med J.
197 Poster EC, Pelletier LR, Kay K. (1991). A retrospective cohort study of falls in a psychiatric inpatient setting. Hosp Community Psychiatry.
198 Tay SE, Quek CS, Pariyasami S, et al. (2000). Fall incidence in a state psychiatric hospital in singapore. J Psychosoc Nurs Ment Health Serv.
199 Tsai YF, Witte N, Radunzel M, et al. (1998). Falls in a psychiatric unit. Appl Nurs Res.
200 de Carle AJ, Kohn R. (2000). Electroconvulsive therapy and falls in the elderly. J Ect.
201 de Carle AJ, Kohn R. (2001). Risk factors for falling in a psychogeriatric unit. Int J Geriatr Psychiatry.
202 Rapport LJ, Hanks RA, Millis SR, et al. (1998). Executive functioning and predictors of falls in the rehabilitation setting. Arch Phys Med Rehabil.
203 Rapport LJ, Webster JS, Flemming KL, et al. (1993). Predictors of falls among right-hemisphere stroke patients in the rehabilitation setting. Arch Phys Med Rehabil.
204 Salgado R, Lord SR, Packer J, et al. (1994). Factors associated with falling in elderly hospital patients. Gerontology.
205 Salgado RI, Lord SR, Ehrlich F, et al. (2004). Predictors of falling in elderly hospital patients. Arch Gerontol Geriatr.
206 Teasell R, McRae M, Foley N, et al. (2002). The incidence and consequences of falls in stroke patients during inpatient rehabilitation: Factors associated with high risk. Arch Phys Med Rehabil.
207 Graf E. Pediatric hosptial falls: Development of a predictor model to guide pediatric clincial practice.
208 Vassallo M, Vignaraja R, Sharma JC, et al. (2004). Predictors for falls among hospital inpatients with impaired mobility. J R Soc Med.
209 Stein J, Viramontes BE, Kerrigan DC. (1995). Fall-related injuries in anticoagulated stroke patients during inpatient rehabilitation. Arch Phys Med Rehabil.
210 Bond A, Molnar F, Li M, et al. (2005). The risk of hemorrhagic complications in hospital in-patients who fall while receiving antithrombotic therapy. Thrombosis Journal.
211 Spector W, Shaffer T, Potter DE, et al. (2007). Risk factors associated with the occurrence of fractures in u.S. Nursing homes: Resident and facility characteristics and prescription medications. J Am Geriatr Soc.
212 Coker E, Oliver D. (2003). Evaluation of the stratify falls prediction tool on a geriatric unit. Outcomes Manag.
213 Hendrich AL. (1989). Prediction and prevention of patient falls. Image J Nurs Sch.
214 Hendrich AL, Nyhuis A, Kippenbrock T, et al. (1995). Hospital falls: Development of a predictive model for clinical practice. Appl Nurs Res.
215 Nyberg L, Gustafson Y. (1996). Using the downton index to predict those prone to falls in stroke rehabilitation. Stroke.
216 Vassallo M, Stockdale R, Sharma JC, et al. (2005). A comparative study of the use of four fall risk assessment tools on acute medical wards. J Am Geriatr Soc.
217 Morse JM, Morse RM. (1988). Calculating fall rates: Methodological concerns. QRB Qual Rev Bull.
218 O'Connell B, Myers H. (2002). The sensitivity and specificity of the morse fall scale in an acute care setting. J Clin Nurs.
219 Myers H, Nikoletti S. (2003). Fall risk assessment: A prospective investigation of nurses' clinical judgement and risk assessment tools in predicting patient falls. Int J Nurs Pract.
220 Eagle DJ, Salama S, Whitman D, et al. (1999). Comparison of three instruments in predicting accidental falls in selected inpatients in a general teaching hospital. J Gerontol Nurs.
221 Ruchinskas R. (2003). Clinical prediction of falls in the elderly. Am J Phys Med Rehabil.
222 Lundin-Olsson L, Jensen J, Nyberg L, et al. (2003). Predicting falls in residential care by a risk assessment tool, staff judgement, and history of falls. Aging Clin Exp Res.
223 Lundin-Olsson L, Nyberg L, Gustafson Y. (2000). The mobility interaction fall chart. Physiother Res Int.
224 Downton JH, Andrews K. (1991). Prevalence, characteristics and factors associated with falls among the elderly living at home. Aging (Milano).
225 Rosendahl E, Lundin-Olsson L, Kallin K, et al. (2003). Prediction of falls among older people in residential care facilities by the downton index. Aging Clin Exp Res.
226 Browne JA, Covington BG. (2004). Embedding clinical indicators into nursing documentation. Medinfo.
227 Browne JA, Covington BG, Davila Y. (2004). Using information technology to assist in redesign of a fall prevention program. J Nurs Care Qual.
228 Volrathongchai K. (2005). Predicting falls among the elderly residing in long-term care facilities using knowledge discovery in databases [Dissertation].
229 Moller J. (2005). Current costing models: Are they suitable for allocating health resources? The example of fall injury prevention in australia. Accid Anal Prev.
230 Panneman MJ, Goettsch WG, Kramarz P, et al. (2003). The costs of benzodiazepine-associated hospital-treated fall injuries in the eu: A pharmo study. Drugs Aging.
231 Scuffham P, Chaplin S, Legood R. (2003). Incidence and costs of unintentional falls in older people in the united kingdom. J Epidemiol Community Health.
232 Colon-Emeric CS, Schenck A, Gorospe J, et al. (2006). Translating evidence-based falls prevention into clinical practice in nursing facilities: Results and lessons from a quality improvement collaborative. J Am Geriatr Soc.
233 Oliver D, Connelly JB, Victor CR, et al. (2007). Strategies to prevent falls and fractures in hospitals and care homes and effect of cognitive impairment: Systematic review and meta-analyses. BMJ.
234 Oliver D, Hopper A, Seed P. (2000). Do hospital fall prevention programs work? A systematic review. J Am Geriatr Soc.
235 Oliver D, Connelly JB, Victor CR, et al. (2007). Strategies to prevent falls and fractures in hospitals and care homes and effect of cognitive impairment: Systematic review and meta-analyses. BMJ.
236 Evans D, Wood J, Lambert L. (2003). Patient injury and physical restraint devices: A systematic review. Journal of Advanced Nursing.
237 Vassallo M, Wilkinson C, Stockdale R, et al. (2005). Attitudes to restraint for the prevention of falls in hospital. Gerontology.
238 Evans D, Wood J, Lambert L. (2002). A review of physical restraint minimization in the acute and residential care settings. J Adv Nurs Dec.
239 Kwok T, Mok F, Chien WT, et al. (2006). Does access to bed-chair pressure sensors reduce physical restraint use in the rehabilitative care setting?. J Clin Nurs.
240 Kelly KE, Phillips CL, Cain KC, et al. (2002). Evaluation of a nonintrusive monitor to reduce falls in nursing home patients. J Am Med Dir Assoc.
241 Mulrow CD, Gerety MB, Kanten D, et al. (1994). A randomized trial of physical rehabilitation for very frail nursing home residents. Jama.
242 Rubenstein LZ, Robbins AS, Josephson KR, et al. (1990). The value of assessing falls in an elderly population. A randomized clinical trial. Ann Intern Med.
243 Choi JH, Moon JS, Song R. (2005). Effects of sun-style tai chi exercise on physical fitness and fall prevention in fall-prone older adults. J Adv Nurs.
244 Nowalk MP, Prendergast JM, Bayles CM, et al. (2001). A randomized trial of exercise programs among older individuals living in two long-term care facilities: The fallsfree program. J Am Geriatr Soc.
245 Bakarich A, McMillan V, Prosser R. (1997). The effect of a nursing intervention on the incidence of older patient falls. Aust J Adv Nurs.
246 Klay M, Marfyak K. (2005). Use of a continence nurse specialist in an extended care facility. Urol Nurs.
247 Bischoff HA, Stahelin HB, Dick W, et al. (2003). Effects of vitamin d and calcium supplementation on falls: A randomized controlled trial. J Bone Miner Res.
248 Flicker L, MacInnis RJ, Stein MS, et al. (2005). Should older people in residential care receive vitamin d to prevent falls? Results of a randomized trial. J Am Geriatr Soc.
249 Jensen J, Nyberg L, Rosendahl E, et al. (2004). Effects of a fall prevention program including exercise on mobility and falls in frail older people living in residential care facilities. Aging Clin Exp Res.
250 Hofmann MT, Bankes PF, Javed A, et al. (2003). Decreasing the incidence of falls in the nursing home in a cost-conscious environment: A pilot study. J Am Med Dir Assoc.
251 Haines TP, Bennell KL, Osborne RH, et al. (2004). Effectiveness of targeted falls prevention programme in subacute hospital setting: Randomised controlled trial. BMJ.
252 Jensen J, Lundin-Olsson L, Nyberg L, et al. (2002). Fall and injury prevention in older people living in residential care facilities. A cluster randomized trial. Ann Intern Med.
253 Healey F, Monro A, Cockram A, et al. (2004). Using targeted risk factor reduction to prevent falls in older in-patients: A randomised controlled trial. Age Ageing.
254 McMurdo ME, Millar AM, Daly F. (2000). A randomized controlled trial of fall prevention strategies in old peoples' homes. Gerontology.
255 Vassallo M, Vignaraja R, Sharma JC, et al. (2004). The effect of changing practice on fall prevention in a rehabilitative hospital: The hospital injury prevention study. J Am Geriatr Soc.
256 Kerse N, Butler M, Robinson E, et al. (2004). Fall prevention in residential care: A cluster, randomized, controlled trial. J Am Geriatr Soc.
257 Semin-Goossens A, van der Helm JM, Bossuyt PM. (2003). A failed model-based attempt to implement an evidence-based nursing guideline for fall prevention. J Nurs Care Qual.
258 Rubinson L, Wu AW, Haponik EE, et al. (2005). Why is it that internists do not follow guidelines for preventing intravascular catheter infections?. Infect Control Hosp Epidemiol.
259 Cabana MD, Rand CS, Powe NR, et al. (1999). Why don't physicians follow clinical practice guidelines?: A framework for improvement. JAMA.
260 Fonda D, Cook J, Sandler V, et al. (2006). Sustained reduction in serious fall-related injuries in older people in hospital. Med J Aust.
261 Schwendimann R, Buhler H, De Geest S, et al. (2006). Falls and consequent injuries in hospitalized patients: Effects of an interdisciplinary falls prevention program. BMC Health Serv Res.
262 Lane AJ. (1999). Evaluation of the fall prevention program in an acute care setting. Orthop Nurs.
263 Lauritzen JB, Petersen MM, Lund B. (1993). Effect of external hip protectors on hip fractures. Lancet.
264 O'Halloran PD, Cran GW, Beringer TR, et al. (2004). A cluster randomised controlled trial to evaluate a policy of making hip protectors available to residents of nursing homes. Age Ageing.
265 O'Halloran PD, Murray LJ, Cran GW, et al. (2005). The effect of type of hip protector and resident characteristics on adherence to use of hip protectors in nursing and residential homes--an exploratory study. Int J Nurs Stud.
266 Ray WA, Taylor JA, Brown AK, et al. (2005). Prevention of fall-related injuries in long-term care: A randomized controlled trial of staff education. Arch Intern Med.