# Acknowledgments

Without a doubt, this could not have been accomplished without the contribution and dedication of many people, both internally and externally to the Agency for Healthcare Research and Quality (AHRQ). A special note of gratitude is extended to each author and peer reviewer who willingly shared their expertise and dedication to making health care better and safer. This project would not have been possible without financial support from the Robert Wood Johnson Foundation and AHRQ, as well as the time authors committed to this project. Invaluable support was given by Carolyn Clancy, Helen Burstin, Tonya Cooper, Susan Hassmiller, David Lanier, and David Meyers throughout the 2-year process of bringing this project together.

Sincere gratitude is also extended to AHRQ’s Office of Communications and Knowledge Transfer (OCKT), specifically Randie Siegel and Sandy Cummings (project oversight), David I. Lewin (copyediting/production management), and Morgan Liskinsky (marketing plan). Further gratitude is extended to OCKT’s editorial contractors (Helen Fox, Roslyn Rosenberg, and Daniel Robinson). Additional thanks go to Joy Solomita, of AHRQ’s Center for Primary Care, Prevention, and Clinical Partnerships, for all her efforts during the finalization process.

Lastly, this book was dependent upon the invaluable assistance of Caryn McManus, Reneé McCullough, Lynette Lilly, and the other librarians throughout the country who helped search for and retrieve thousands of articles and book chapters.

This book is dedicated to nurses everywhere.