# 10 Current UMLS Release Information

The UMLS is updated twice each year in May (AA release) and November (AB release). For information about UMLS releases, licensing, and metadata, visit the current UMLS release Web page (http://www.nlm.nih.gov/research/umls/knowledge_sources/metathesaurus/release/index.html).