# 7 Using the UMLS Terminology Services (UTS)

The UMLS Terminology Services (UTS) provides access to the UMLS Knowledge Sources through a web browser or through an application programming interface (API).

Users are encouraged to consult the UTS (https://uts.nlm.nih.gov/uts/) to find API documentation and information on downloading the UMLS release files.

## 7.1 Downloading the UMLS Knowledge Sources

UMLS licensees may access the UTS and create an account with an identity provider of their choosing. Licensees can download the current UMLS Knowledge Sources (https://www.nlm.nih.gov/research/umls/licensedcontent/umlsknowledgesources.html). Archives of UMLS releases are kept and made available for several previous years. For detailed technical specifications and installation instructions refer to the README.TXT file available within the UMLS release files.

## 7.2 System Architecture

The UTS, made available in December 2010, replaced the UMLS Knowledge Source Server (UMLSKS). The UTS provides access to the UMLS Knowledge Sources through a browser-based application and a Web services client. The UTS features the following enhancements:

- Highly responsive search engine for quick retrieval
- Increased capacity by an order of magnitude
- High availability via co-location redundancy
- More intuitive graphical user interface
- Real-time monitoring and collection of statistics
- Integration of licensing and reporting requirements

## 7.3 Querying the UTS

### 7.3.1 Metathesaurus Browser

The UTS allows the user to request information about particular Metathesaurus concepts, including attributes such as the concept's definition, its semantic types, and the concepts that are related to it.

Basic concept information includes the Metathesaurus unique identifier of the concept, the preferred name for the concept, and the names and sources of all terms that comprise that concept. Additional concept information often includes a definition and the source of that definition. Semantic type information is also included. Information about the hierarchical contexts of Metathesaurus concepts is readily available in the system. Related concepts are easily found.

An important perspective on the Metathesaurus is source specific data. It is possible to query the server by limiting the query to a particular vocabulary. The user may wish to see the ancestors or descendants for a term in just a particular vocabulary, or the user may wish to see just the synonyms for a particular term in a particular vocabulary.

### 7.3.2 Semantic Network Browser

The Semantic Network contains information about semantic types and their relationships. The implementation of the network module computes the relationships between semantic types using the inheritance property of the network type hierarchy. Information in the Semantic Network can be browsed for semantic types and the relationships between them.

It is possible to retrieve all the relations between a pair of types. For example, "treats", "prevents", and "complicates" would be listed, among others, as potential relationships between drugs and diseases. It is also possible to retrieve an exhaustive list of all related types in the network. Queries can be made about the definition, unique identifier, tree number, ancestors, parents, children, and descendants of a semantic type or relation.

## 7.4 Gaining Access to the UTS

Access to the UTS is available to anyone who has signed the UMLS Metathesaurus License Agreement and activated a UTS account. First time users should click “Sign Up” on the UTS homepage (https://uts.nlm.nih.gov/uts/) to begin the license request and UTS account activation process. Any questions or problems should be addressed via e-mail to NLM Customer Support (https://support.nlm.nih.gov/).

## 7.5 UTS

The following are available on the UTS:

- UMLS licensing
- UTS profile
- API documentation
- Data browsers and tools
- File downloads
- Help information