# Publication Details

Publisher: National Institute of Environmental Health Sciences

Publishing Location: Research Triangle Park, NC

DOI: https://doi.org/10.22427/NIEHS-00

Official citation: Roberts GK, Stout MD, editors. Specifications for the Conduct of Toxicity Studies by the Division of Translational Toxicology at the National Institute of Environmental Health Sciences. Research Triangle Park, NC: National Institute of Environmental Health Sciences; 2023.