# Collaborators

- Division of Translational Toxicology, National Institute of Environmental Health Sciences, Research Triangle Park, North Carolina, USA
  Editors-in-Chief
  G.K. Roberts, Ph.D.
  M.D. Stout, Ph.D.