# References

Abbott Laboratories (1998). Package insert for Biaxin (clarithromycin), Chicago, IL.
Albani F., Riva R, and Baruzzi, A. (1993). Clarithromycin-carbamazepine interaction. Case Report. Epilepsia 34, 161–162.8422851
Alder, J., Hutch T., Meulbroek J.A., and Clement, J.C. (1994). Treatment of experimental Toxoplasma gondii infection by clarithromycin-based combination therapy with minocycline or pyrimethamine. J. Acquir. Immune Defic. Syndr. 7, 1141–1148.7932081
Alvarez-Elcoro, S., and Enzler, M.J. (1999). The macrolides: Erythromycin, clarithromycin, and azithromycin. Mayo Clin. Proc. 74, 613–634.10377939
Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Araujo, F.G., Prokocimer, P., Lin, T., and Remington, J.S. (1992). Activity of clarithromycin alone or in combination with other drugs for treatment of murine toxoplasmosis. Antimicrob. Agents Chemother. 36, 2454–2457.1489188
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Bahal, N., and Nahata, M.C. (1992). The new macrolide antibiotics: Azithromycin, clarithromycin, dirithromycin, and roxithromycin. Ann. Pharmacother. 26, 46–55.1318761
Barradell, L.B., Plosker, G.L., and McTavish, D. (1993). Clarithromycin. A review of its pharmacological properties and therapeutic use in Mycobacterium avium-intracellulare complex infection in patients with acquired immunodeficiency syndrome. Drugs 46, 289–312.7691518
Bick, R.L., Ed. (1993). Hematology Clinical and Laboratory Practice, pp. 185–201, Mosby Press, St. Louis.
Brown, B.A., Wallace, R.J., Onyi, G.O., DeRosas, V., and Wallace, R., III. (1992). Activities of four macrolides, including clarithromycin, against Mycobacterium fortuitum, Mycobacterium chelonae, and M chelonae-like organisms. Antimicrob. Agents Chemother. 36, 180–184.1317144
Centers for Disease Control and Prevention (CDC) (1997). USPHS/IDSA guidelines for the prevention of opportunistic infections in persons infected with human immunodeficiency virus. MMWR 46 (no. RR-12), 1–46.
Chaisson, R.E., Moore, R.D., Richman, D.D., Keruly, J., and Creagh, T. (1992). Incidence and natural history of Mycobacterium avium-complex infections in patients with advanced human immunodeficiency virus disease treated with zidovudine. Am. Rev. Respir. Dis. 146, 285–289.1362634
Chang, H.R, and Pechère, J.-C.F. (1988). In vitro effects of four macrolides (roxithromycin, spiramycin, azithromycin [CP-62,993], and A-56268) on Toxoplasma gondii. Antimicrob. Agents Chemother. 32, 524–529.2837140
Chapelsky, M.C., Nix, D.E., Cavanaugh, J.C., Wilton, J.H., Norman, A., and Schentag, J.J. (1992). Renal tubular enzyme effects of clarithromycin in comparison with gentamicin and placebo in volunteers. Drug Saf. 7, 304–309.1355971
Chow, R.F., Sutton, P.A., and Hamburger, A.W. (1991). Sensitivity of erythroid progenitor colonies to erythropoietin in azidothymidine treated immunodeficient mice. Brit. J. Haematol. 77, 139–144.2004015
Chu, S.-Y., Sennello, L. T., and Bunnell, S.T. (1991). Pharmacokinetics of clarithromycin in subjects with varying renal function. In Program and Abstracts of the 31st Interscience Conference on Antimicrobial Agents and Chemotherapy; Chicago, IL. Abstract 514.
Coffin, J. M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Craft, J.C., and Siepman, N. (1993). Overview of the safety profile of clarithromycin suspension in pediatric patients. Pediatr. Infect. Dis. J. 12, S142–S147.8295816
Dautzenberg, B., Truffot, C., Legris, S., Mehoyas, M., Berlie, H.C., Mercat, A., Chevret, S., and Grosset, J. (1991a). Activity of clarithromycin against Mycobacterium avium infection in patients with the acquired immune deficiency syndrome. Am. Rev. Respir. Dis. 144, 564–569.1832527
Dautzenberg, B., Saint-Marc, T., Averous, V., Routkovsky-Norval, C., Breux, J.P., Kristetter, M., Eliazewitch, M., Mondain, V., Legris, S., and Grosset, J. (1991 b). Clarithromycin-containing regimens in the treatment of 54 AIDS patients with disseminated Mycobacterium avium-intracellulare infection. In Program and Abstracts of the 31st Interscience Conference on Antimicrobial Agents and Chemotherapy; Chicago, IL. Abstract 293.
Dautzenberg, B., Hazebroucq, J., and Chauvin, J.P. (1992). Clarithromycin in 100 AIDS patients with disseminated M. avium infection. In Program and Abstracts of the 32nd Interscience Conference on Antimicrobial Agents and Chemotherapy; Anaheim, CA. Abstract 893.
Dautzenberg, B., Saint-Marc, T., Mehoyas, M.C., Eliaszewitch, M., Haniez, F., Rogues, A.M., De Wit, S., Cotte, L., Chauvin, J.P., and Grosset, J. (1993). Clarithromycin and other antimicrobial agents in the treatment of disseminated Mycobacterium avium infections in patients with acquired immunodeficiency syndrome. Arch. Intern. Med. 153, 368–372.8427539
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1095–1121.
Faris, M.A., Raasch, R.H., Hopfer, R.L., and Butts, J.D. (1998). Treatment and prophylaxis of disseminated Mycobacterium avium complex in HIV-infected individuals. Ann. Pharmacother. 32, 564–573.9606478
Fernandez-Martin, J., Leport, C., Morlat, P., Mehoyas, M.-C., Chauvin, J.-P., and Vilde, J.-L. (1991). Pyrimethamine-clarithromycin combination for therapy of acute Toxoplasma encephalitis in patients with AIDS. Antimicrob. Agents Chemother. 35, 2049–2052.1836943
Ferrero, J.L., Bopp, B.A., Marsh, K.C., Quigley, S.C., Johnson, M.J., Anderson, D.J., Lamm, J.E., Tolman, K.G., Sanders, S.W., Cavanaugh, J.H., and Sonders, R.C. (1990). Metabolism and disposition of clarithromycin in man. Drug Metab. Dispos. 18, 441–446.1976065
Franschini, F., Scaglione, F., Pintucci, G., Maccarinelli, G., Dugnani, S., and Demartini, G. (1991a). The diffusion of clarithromycin and roxithromycin into nasal mucosa, tonsil and lung in humans. J. Antimicrob. Chemother. 27 (Suppl. A), 61–65.
Franschini, F., Scaglione, F., Pintucci, J.P., Cogo, R., and Tassi, G.F. (1991b). Clarithromycin and its 14-OH metabolite. Pharmacokinetics and tissue distribution in humans. In Program and Abstracts of the 31st Interscience Conference on Antimicrobial Agents and Chemotherapy, Chicago, IL. Abstract 512.
Freireich, E.J., Gehan, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Can. Chem. Rep. 50, 219–244.
Gogu, S.R., Beckman, B.S., Wilson, R.B., Agrawal, K.C. (1995). Inhibitory effects of zidovudine in erythroid progenitor cells: Reversal with a combination of erythropoietin and interleukin-3. Biochem. Pharmacol. 50, 413–419.7646543
Goldman, M.P., and Longworth, D.L. (1993). The role of azithromycin and clarithromycin in clinical practice. Cleve. Clin. J. Med. 60, 359–364.8403355
Goldschmidt, RH., and Dong, B.J. (1992). Current Report - HIV. Treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Gottlieb, M.S., Schroff, R, Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, RA., and Saxon, A. (1981). Pneumocystis carinii Pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immuno-deficiency. New Engl. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Griffith, D.E. (1999). Risk-benefit assessment of therapies for Mycobacterium avium complex infections. Drug Saf 21, 137–152.10456381
Guay, D.R.P., Patterson, D.R., Seipman, N., and Craft, J.C. (1993). Overview of the tolerability profile of clarithromycin in preclinical and clinical trials. Drug Saf 8, 350–364.8504017
Gupta, S., Blahunka, K., Dellerson, M., Craft, J.C., and Smith, T. (1992). Interim results of safety and efficacy of clarithromycin (C) in the treatment of disseminated Mycobacterium avium complex (MAC) infection in patients (Pts) with AIDS. In Program and Abstracts of the 32nd Interscience Conference on Antimicrobial Agents and Chemotherapy, Anaheim, CA. Abstract 892.
Gustavson, L.E., Chu, S.-Y., Mackenthum, A., Gupta, S.D., and Craft, J.C. (1993). Drug interaction between clarithromycin and oral zidovudine in HIV-1 infected patients. Clin. Pharmacol. Ther. 53, 163.
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992). Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Heifets, L.B., Lindholm-Levy, P.J., and Comstock, R.D. (1992). Clarithromycin minimal inhibitory and bactericidal concentrations against Mycobacterium avium. Am. Rev. Respir. Dis. 145, 856–858.1532486
Honig, P., Wortham, D., Zamani, K., Conner, D., and Cantilena, L. (1993). Effect of erythromycin, clarithromycin, and azithromycin on the pharmacokinetics of terfenadine. Clin. Pharmacol. Therap. 53, 161.
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18, 5–13.2464649
Jonckheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Kirst, H.A., and Sides, G.D. (1989). New directions for macrolide antibiotics: Structural modifications and in vitro activity. Antimicrob. Agents Chemother. 33, 1413–1418.2684004
Kohno, Y., Ohta, K., Suwa, T., and Suga, T. (1990a). Autobacteriographic studies of clarithromycin and erythromycin in mice. Antimicrob. Agents Chemother. 34, 562–567.2140497
Kohno, Y., Yoshida, H., Suwa, T., and Suga, T. (1990b). Uptake of clarithromycin by rat lung cells. J. Antimicrob. Chemother. 26, 503–513.2147673
McConnell, S.A., and Amsden, G.W. (1999). Review and comparison of advanced-generation macrolides clarithromycin and dirithromycin. Pharmacotherapy 19, 404–415.10212011
Malaty, L.I., and Kuper, J.J. (1999). Drug interactions of HIV inhibitors. Drug Saf 20, 147–169.10082072
Mansuri, M. M., Hitchcock, M. J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, RZ., and Martin, J.C. (1990). Comparison of in vitro biologic and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrobial Agents Chemother. 34, 637–641.
Maronpot, R.R., Boorman, G.A., and Gaul, B.W. (1999). Pathology of the Mouse, 1^st^ ed., p. 339. Cache River Press, Vienna, IL.
Masur, H. (1993). Recommendations on prophylaxis and therapy for disseminated Mycobacterium avium complex disease in patients infected with the human immunodeficiency virus. New Engl. J. Med 329, 898–904.8395019
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Vande Stouwe, R.A., Holzman, RS., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. New Engl. J. Med 305, 1431–1438.6975437
National Institute of Environmental Health Sciences (1999). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Isoniazid Combinations Administered by Gavage to Swiss (CD-1® Mice. NIEHS AIDS Therapeutics Toxicity Report No.3. NIH Publication 99-3941. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, NC.
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/α-Interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, N.C.
Ong, E.L.C. (1999). Prophylaxis against disseminated Mycobacterium avium complex in AIDS. J. Infect. 38, 6–8.10090497
Pallasch, T.J. (1993). Antibiotics for acute orofacial infections. J. Calif. Dent. Assoc. 21, 34–44.
Physician’s Desk Reference (PDR) (1996). 50th ed., pp. 1158–1163. Medical Economics Data Production Co., Montvale, NJ.
Piscitelli, S.C., Flexner, C., Minor, J.R., Polis, M.A., and Masur, H. (1996). Drug interactions in patients infected with human immunodeficiency virus. Clin. Infec. Dis. 23, 685–693.8909827
Polis, M.A., Piscitelli, S.C., Vogel, S., Witebsky, F.G., Conville, P.S., Petty, B., Kovacs, J.A., Davey, R.T., Walker, R.E., Falloon, J., Metcalf, J.A., Craft, C., Lane, H.C., and Masur, H. (1997). Clarithromycin lowers plasma zidovudine levels in persons with human immunodeficiency virus infection. Antimicrob. Agents Chemother. 41, 1709–1714.9257746
Rao, G.N., Lindamood, C., Heath, J.E., Farnell, D.R, and Giles, H.G. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Richens, A., Chu, S.-Y., Sennello, L.T., and Sonders, R.C. (1990). Effect of multiple doses of clarithromycin (C) on the pharmacokinetics (pks) of carbamazepine (Carb). In Program and Abstracts of the 30th Interscience Conference on Antimicrobial Agents and Chemotherapy; Atlanta, GA. Abstract 760.
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infec. Dis. Clin. North Am. 2, 397–497.2462584
Richman, D.D., Fischl, M.A., Grieco, M.H., Gottlieb, M.S., Volberding, P.A., Laskin, O.L., Leedom, J.M., Groopman, J.E., Mildvan, D., Hirsch, M.S., Jackson, G.G., Durack, D.T., Phil, D., Nusinoff-Lehrman, S., and the AZT Collaborative Working Group (1987). The toxicity of azidothymidine (AZT) in the treatment of patients with AIDS and AIDS-related complex. New Engl. J. Med. 4, 192–197.
Saint Georgiev, V. (1994). Management of toxoplasmosis. Drugs 48, 179–188.7527323
Saint-Marc, T., and Touraine, J.L. (1991). Clinical experience with a combination of clarithromycin and clofaximine in the treatment of disseminated M avium infections in AIDS patients. In Program and Abstracts of the 31st Interscience Conference on Antimicrobial Agents and Chemotherapy; Chicago, IL. Abstract 237.
Scheffe, H. (1953). A method for judging all contrasts in the analysis of variance. Biometrika 40, 87–104.
Sheehan, D.C., and Rapchak, B.H. (1980). Gomori’s modified iron stain (Pussian Blue). In Theory and Practice of Histotechnology, 2nd ed., p. 218. Battelle Press, Columbus, OH.
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp. 96–104. McGraw-Hill, New York.
Siegle, F.P., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. New Engl. J. Med. 305, 1439–1444.6272110
Snedecor, G.W., and Cochran, W.G. (1967a). Analysis of Variance. In Statistical Methods, 6th ed., pp. 258–275. Iowa State University Press, Ames, IA.
Snedecor, G.W., and Cochran, W.G. (1967b). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames, IA.
Snower, D.P., and Weil, S.C. (1993). Changing etiology of macrocytosis. Am. J. Clin. Pathol. 99, 57–60.8422018
Sokal, R.R., and Rohlf, F.J. (1969). Kruskal-Wallis Test. In Biometry., pp. 370–371, 388–389. W.H. Freeman and Co., San Francisco.
Stein, G.E., and Havlichek, D.H. (1992). The new macrolide antibiotics. Azithromycin and clarithromycin. Postgrad. Med. 92, 269–282.1319579
Sturgill, M.G., and Rapp, R.P. (1992). Clarithromycin: Review of a new macrolide antibiotic with improved microbiologic spectrum and favorable pharmacokinetic and adverse effect profiles. Ann. Pharmacother. 26, 1099–1108.1421677
Sturrock, R.R. (1983). A light microscopic and scanning electron microscopic study of intraventricular macrophages in the brains of aged mice. J. Anat. 136, 769–771.
Sturrock, R.R. (1988). An ultrastructural study of intraventricular macrophages in the brains of aged mice. Anat. Anz. (Jena) 165, 283–290.
Thompson, M.B., Dunnick, J.K., Sutphin, M.E., Giles, H.D., Irwin, R.D., and Prejean, J.D. (1991). Hematologic toxicity of AZT and ddC administered as single agents and in combination to rats and mice. Fundam. Appl. Toxicol. 17, 159–176.1655546
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F1 mice. Drug Metab. Dispos. 21, 189–193.8095218
Vance, E., Watson-Bitar, M., Gustavson, L., Kazanjian, P. (1995). Pharmacokinetics of clarithromycin and zidovudine in patients with AIDS. Antimicrob. Agents Chemother. 39, 1355–1360.7574530
Vince, R, Hua, M., Brownell, J., Daluge, S., Fangchem, L., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against Human Immunodeficiency Virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics 28, 519–531.5037867
Wright, J., and Pharm, D. (1998). Current strategies for the prevention and treatment of disseminated Mycobacterium avium complex infection in patients with AIDS. Pharmacotherapy 18, 738–747.9692648