# Peer Review

The draft report on the reproductive, developmental, and general toxicity studies of 3'-azido-3 '-deoxythymidine (AZT) and clarithromycin combinations will be evaluated by reviewers. These reviewers serve as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of the study are appropriate and ensure that this reproductive, developmental, and general toxicity studies report presents the experimental results and conclusions fully and clearly. The comments of the reviewers will be reviewed prior to finalization of this document. Changes will be made such that the concerns of the reviewers will be addressed to the extent possible.

- Jay Gandy, Ph.D.
  Department of Environmental and Occupational Health University of Arkansas for Medical Sciences Little Rock, AR
- Warren W. Ku
  Drug Safety Evaluation
  Pfizer Global Research and Development
  Groton, CT