# Discussion and Conclusions

Two reproductive, developmental, and general toxicity studies were conducted in Swiss (CD-1®) mice treated with AZT alone, clarithromycin alone, and combinations of AZT and clarithromycin. In the first study, the dosages of AZT were 200 and 400 mg/kg per day, and the dosages of clarithromycin were 500, 1,250, and 2,500 mg/kg per day. The clarithromycin contained numerous excipients included by the manufacturer in the preparation of these antibiotic tablets for human therapeutic use. The dose formulations were administered by oral gavage for approximately 20 days to male mice, approximately 30 days to female-A mice, and approximately 10 days to female-B mice. Excessive mortality occurred in male and female groups treated with 1,250 or 2,500 mg/kg clarithromycin alone or in combination with AZT. The mortality was attributed to toxicity in multiple vital organs and localized complications in the stomach associated with chronic dilatation from the large volume of thick gavaged material. The numerous excipients likely contributed to the viscosity of the clarithromycin formulations, resulting in chronic dilatation of the stomach. The local antibacterial action of clarithromycin apparently altered the normal flora in the stomach lumen, resulting in a fungal overgrowth and inflammatory lesions. In addition to the high mortality rate associated with the higher dosages of clarithromycin, cytoplasmic vacuolization of phagocytic cells occurred in many tissues (brain, bone marrow, spleen, liver, kidney, thymus, lymph nodes). An example of this lesion in the choroid plexus of the brain is illustrated in Plates 3 and 4. Groups treated with AZT and clarithromycin combinations developed severe hematopoietic toxicity with bone marrow depression, anemia, and high mortality rates. Reduced fertility also occurred in groups treated with higher doses of clarithromycin alone or in combination with AZT.

Because of excessive mortality in the study conducted with unpurified clarithromycin, a second study was conducted using purified clarithromycin at lower dosage levels. Male and female Swiss (CD-1®) mice were treated by gavage with AZT alone (200 or 400 mg/kg per day), clarithromycin alone (250, 500, or 1,000 mg/kg per day), and combinations of AZT and clarithromycin. As in the first study, male mice were treated for approximately 20 days, female-A mice for approximately 30 days, and female-B mice for approximately 10 days.

Treatment with AZT alone at 400 mg/kg resulted in higher plasma concentrations in male mice treated for approximately 20 days than in pregnant female-A mice treated for approximately 30 days. This difference may be a reflection of the physiological state of pregnancy. Administration of 400 mg/kg AZT in combination with 250,500, or 1,000 mg/kg clarithromycin resulted in peak plasma concentrations of AZT decreasing in both sexes as the oral dose of clarithromycin increased. The patterns of β-D-glucuronide of AZT (GAZT) plasma concentrations were similar to the AZT plasma concentrations. The 3’-amino-3’-deoxythymidine (AMT) concentrations show some clarithromycin dose-related pattern in the female-A mice but not in the males. Drug interactions similar to this have been reported previously in AIDS patients treated With clarithromycin and AZT (Polis et al., 1997). The authors postulated that the lower plasma levels of AZT may be related to altered absorption of AZT and recommended that administration of AZT and clarithromycin to AIDS patients be separated by at least 2 hours. Results of this study indicate that the metabolism and disposition of AZT in pregnant female mice treated with AZT/clarithromycin combinations for approximately 30 days may be slower than in male mice treated for approximately 20 days. This could also be a reflection of altered absorption of AZT secondary to clarithromycin-induced changes in gastrointestinal motility. The physiological state of pregnancy as well as the differences in the duration of treatment could also influence the metabolism of AZT.

There was no marked dose- or time-related trend for plasma concentrations of clarithromycin from 30 to 240 minutes after oral administration, either alone or in combination with 400 mg/kg AZT. However, the plasma concentrations of clarithromycin in pregnant females were several-fold higher than in the males at all time points included in this study, indicating slower elimination of clarithromycin in pregnant females than in males. One of the reasons for higher concentrations of clarithromycin in pregnant females may be due to longer duration of treatment of females (30 days) compared to males (20 days).

Treatment with AZT alone resulted in measurable evidence of hematopoietic toxicity manifested by mild decreases in red blood cell, hemoglobin, and hematocrit values and mild to moderate increases in mean cell volume (MCV) and red cell distribution width values in both male and female mice. Hematopoietic cell proliferation of the spleen and slight hemosiderosis of the spleen accompanied the mild alterations in erythrocyte parameters. A minor degree of cytoplasmic alteration believed to represent glycogen depletion occurred in hepatocytes in male and female-A mice, and a slight reduction in body weight gain occurred in the high-dose female-A group. Mortality and significant clinical alterations did not accompany the slight hematopoietic toxicity that occurred in male and female mice treated with AZT.

The macrocytosis that accompanied the slight anemia was related to dose and duration of treatment, as the severity was greatest in female-A mice treated for approximately 30 days when compared to the male mice treated for approximately 20 days. Hematological alterations in female-B mice treated with AZT alone for approximately 10 days were limited to mild elevations in MCV values. Reticulocytosis did not accompany the macrocytosis in any of the male or female treatment groups. The mild macrocytic anemia that occurred with AZT treatment is compatible with the anemia previously reported in mice (Thompson et al., 1991). Macrocytic anemia is a common observation in humans treated with AZT (Richman et al., 1987; Snower and Weil, 1993). The exact mechanism of the erythrocyte macrocytosis is unclear but it likely reflects inhibition of DNA synthesis in erythroid precursors. AZT is directly toxic to erythroid blast forming units (BFU-E) and erythroid colony forming units (CFU-E) in vitro at high concentrations and is antiproliferative in CFU-E at lower concentrations (Gogu et al., 1995). In in vivo studies, AZT has been shown to increase splenic and bone marrow BFU-E in mice and to increase the sensitivity of both splenic and bone marrow BFU-E to erythropoietin (Chow et al., 1991); both effects occur in the absence of an appreciable regenerative response (reticulocytosis), suggesting a maturation block in the erythroid series due to a block in terminal differentiation. AZT has since been shown to down-regulate the erythropoietin receptor in CFU-E and inhibit erythropoietin receptor-mediated signal transduction (Gogu et al., 1995). These mechanisms could inhibit CFU-E proliferation and possibly affect erythropoietin-regulated maturation (Bick, 1993). The absence of reticulocytosis in the presence of a macrocytic anemia subsequent to the administration of AZT in this study is compatible with depression of the erythroid precursors due to impaired DNA synthesis.

Administration of 250 or 500 mg/kg clarithromycin alone did not result in significant toxicity in male or female mice. Administration of 1,000 mg/kg clarithromycin alone resulted in a low incidence of toxicity in male and female mice involving multiple organs, including liver, spleen, bone marrow, kidney, heart, brain, thymus, lymph nodes, and salivary gland. The low incidence of these lesions is likely the result of individual susceptibility to the effects of clarithromycin, as the majority of the mice in these groups did not have lesions. Vacuolization of phagocytic cells occurred in many of these tissues and was especially evident in the spleen, bone marrow, liver, and choroid plexus of the brain. Phagocytic capabilities of the reticuloendothelial cells in lymph nodes, spleen, liver, and bone marrow are easily visualized by the presence of hemosiderin in these tissues. Macrophages with phagocytic capabilities have been demonstrated on the surface of the choroid plexus in the brain of mice (Sturrock, 1983, 1988). Cellular uptake of clarithromycin has been demonstrated in vitro in neutrophils and macrophages (Baradell et al., 1993), but how large amounts of clarithromycin affect macrophage morphology and other cells with phagocytic capabilities in vivo has not been described.

Administration of AZT in combination with clarithromycin resulted in hematopoietic toxicity in male and female-A mice, and the severity of the anemia was far greater than that induced by AZT alone. The anemia was accompanied by bone marrow depletion and hematopoietic cell proliferation and hemosiderosis of the spleen. The anemia was macrocytic in the majority of the treatment groups, but progressed to a microcytic anemia in the highest dose female-A group. Clarithromycin has been previously associated with a nonregenerative normocytic to microcytic anemia (Guay et al., 1993). Reticulocytopenia and sporadic thrombocytosis were also considered to be treatment-related manifestations of hematopoietic toxicity. In general, combination therapy did not appear to enhance toxicity in other tissues as the morphological alterations and the incidence and severity were similar to those induced by clarithromycin alone. Toxicity, in general, was more severe in female-A mice treated for approximately 30 days than in male mice treated for approximately 20 days. Toxicity was least evident in female-B mice treated for approximately 10 days. Toxicological basis for increases in hematological toxicity of AZT+clarithromycin combinations is not known. However, increased hematological toxicity with increasing doses of clarithromycin in combination with a fixed dose of AZT in female-A mice may be due to clarithromycin dose-related increases in plasma concentrations of AZT and clarithromycin and longer duration of treatment than in the males.

Regarding reproductive toxicity, treatment with AZT alone resulted in a slight decline in pregnancy rate, reduced live litter size, increased numbers of resorptions, and a slight decline in total weight per litter. These alterations have been previously reported in mice treated with AZT alone (NIEHS, 1999). Treatment with clarithromycin alone resulted in diminished fertility with a reduction in pregnancy rate, reduction in the number of litters delivered and a reduced litter size. Clarithromycin alone did not cause an increase in gross external alterations (cleft palate) as previously reported (Abbott Laboratories, 1998). Fertility was further reduced in groups treated with combinations of AZT and clarithromycin. Combination therapy resulted in reduced pregnancy rates, reduced live litter size, increased numbers of resorptions and declines in fetal and pup weights per litter. A decreased number of pups surviving to postnatal day 4 also occurred. However, most increases in reproductive and developmental toxic effects in female mice were observed at the combination dose levels that caused increased maternal toxicity as measured by hematological parameters and body weights.

## Conclusions

Two reproductive, developmental, and general toxicity studies were conducted in Swiss (CD-1®) mice treated with AZT (200 or 400 mg/kg per day) and clarithromycin. In the first study, using unpurified clarithromycin formulations (prepared from tablets for human use and containing excipients included by the manufacturer) of 500, 1,250, or 2,500 mg/kg per day, excessive mortality occcurred due to multiple organ toxicity and stomach complications secondary to the large volume of gavaged material and fungal infections. In the second study, mice were treated with AZT and 250,500, or 1,000 mg/kg purified clarithromycin.

Administration of AZT alone resulted in mild hematopoietic toxicity manifested primarily by a slight macrocytic anemia. Administration of 250 or 500 mg/kg clarithromycin alone did not result in significant toxicity in male or female mice. Administration of 1,000 mg/kg clarithromycin resulted in a low incidence of toxicity (cytoplasmic vacuolization of phagocytic cells) in multiple organs.

Administration of AZT (200 or 400 mg/kg) in combination with clarithromycin (250, 500, or 1000 mg/kg) resulted in exacerbation of the hematopoietic toxicity induced by AZT alone. The severity of the anemia with combination therapy was far greater than that induced by AZT alone, and the anemia was accompanied by cellular depletion of the bone marrow and hematopoietic cell proliferation in the spleen. The anemia was macrocytic in the majority of the combination therapy groups but progressed to a microcytic anemia in the female-A group treated with the highest dose of AZT and clarithromycin. Other manifestations of hematopoietic toxicity resulting from combination therapy consisted of reticulocytopenia and thrombocytosis.

Regarding reproductive toxicity, treatment with AZT alone resulted in a slight decline in pregnancy rate, reduced live litter size, increased numbers of resorptions, and a slight decline in total weight per litter. Treatment with clarithromycin alone resulted in diminished fertility with a reduction in pregnancy rate, reduction in the number of litters delivered and reduced litter size. Fertility was further reduced in groups treated with combinations of AZT and clarithromycin. Combination therapy resulted in reduced pregnancy rates, reduced live litter size, increased numbers of resorptions, and declines in fetal and pup weights per litter. A decreased number of pups surviving to postnatal day 4 also occurred. However, the increases in reproductive and developmental toxicity of the therapeutic combinations may be due to increased maternal toxicity. These results indicate that AZT and clarithromycin combinations have the potential to markedly increase the hematopoietic toxicity of either therapy alone.