# Results

In the initial study with AZT (200 or 400 mg/kg per day) and clarithromycin (500, 1,250, or 2,500 mg/kg per day), the dose levels of clarithromycin were too high, resulting in excessive mortality. Clarithromycin dose levels were approximately 2, 5, and 10 times the human therapeutic dose, and 100% mortality occurred in male and female-A groups treated with 2,500 mg/kg clarithromycin alone or in combination with AZT. The mortality was attributed to toxicity in multiple vital organs and localized complications in the stomach associated with chronic dilatation from the large volume of thick gavaged material. The unpurified clarithromycin formulations contained numerous excipients included by the manufacturer in the preparation of these antibiotic tablets for human therapeutic use. The excipients likely contributed to the viscosity of the clarithromycin dosage formulations, resulting in chronic dilatation of the stomach. The local antibacterial action of clarithromycin apparently altered the normal flora in the stomach lumen, resulting in a fungal overgrowth and inflammatory lesions. Other lesions attributed to clarithromycin occurred in the bone marrow, spleen, liver, kidney, heart, brain, thymus, lymph nodes, and salivary gland. Extensive vacuolization of phagocytic cells occurred in the majority of these tissues. Groups treated with AZT and clarithromycin combinations developed severe hematopoietic toxicity with bone marrow depression, anemia, and high mortality. Reduced fertility also occurred in groups treated with higher dosages of clarithromycin alone or in combination with AZT. With the exception of Plates illustrating microscopic lesions caused by clarithromycin at 1,250 mg/kg (considered comparable to the 1,000 mg/kg administered in the second study), the initial study will not be referred to again in this report. The remainder of this report deals with results in Swiss CD-1® mice treated by oral gavage with 200 or 400 mg/kg AZT and 250, 500, or 1,000 mg/kg clarithromycin.

## Survival and Clinical Findings

### Male Mice

Administration of 200 or 400 mg/kg AZT alone or 250, 500, or 1,000 mg/kg clarithromycin alone to male mice for approximately 20 days did not result in mortality. No deaths occurred in any of the male groups treated with combinations of AZT and clarithromycin.

Piloerection, believed to be a nonspecific manifestation of poor health, was the most common clinical finding. Piloerection occurred in 5 and 10 male mice, respectively, treated with 200 and 400 mg/kg AZT alone. Treatment with 500 and 1,000 mg/kg clarithromycin alone resulted in piloerection in 9 and 10 males, respectively. For the male groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the respective incidences of piloerection were 3, 5, and 10. Piloerection occurred in all 10 males in each of the groups treated with 400 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin. Pallor occurred in three male mice treated with 200 mg/kg AZT plus 1,000 mg/kg of clarithromycin and in one and seven males, respectively, treated with 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin. The pallor was believed to be a reflection of the anemia evident in the hematology parameters. An ulcer was seen in the groin area of one male treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin.

### Female-A Mice

Three female-A mice, treated for approximately 30 days, died prior to scheduled sacrifice. One female-A mouse each in the groups treated with 1,000 mg/kg clarithromycin alone, 400 mg/kg AZT plus 500 mg/kg clarithromycin, and 400 mg/kg AZT plus 1,000 mg/kg clarithromycin was sacrificed due to moribund condition. All three mice had piloerection and/or pallor. The female treated with 1,000 mg/kg clarithromycin alone also had sunken eyes and was cold to the touch. Labored breathing, abdominal distention, cold to the touch, and sunken eyes were other clinical findings in the female treated with 400 mg/kg AZT plus 500 mg/kg clarithromycin that died early. Gavage accidents did not occur.

With the exception of piloerection and pallor, most adverse clinical findings occurred in the three mice that were sacrificed moribund prior to scheduled termination. As with the male mice, piloerection was the most common clinical finding. Piloerection occurred in one female-A mouse treated with 400 mg/kg AZT alone and 19 female-A mice treated with 1,000 mg/kg clarithromycin alone. For the groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the respective incidences of piloerection were 1, 2, and 20. For the female-A groups treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the incidences of piloerection were 7, 20, and 20. Pallor occurred in two female-A mice treated with 1,000 mg/kg clarithromycin alone. Pallor did not occur in groups treated with AZT alone. The incidence of pallor generally increased as combination dosages of AZT and clarithromycin increased. The respective incidences of pallor in female-A groups treated with 200 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin were one, zero, and three. For the groups that received 400 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin, the incidences were 13, 19, and 20, respectively. The occurrence of pallor was believed to be a reflection of the anemia evident in the hematology parameters. Other clinical observations documented with a low incidence were sunken eyes, cold to the touch, abdominal distention, and labored breathing.

### Female-B Mice

A total of five female-B mice, treated for approximately 10 days, died prior to scheduled sacrifice. One female-B mouse each died or was sacrificed moribund in the groups treated with 500 mg/kg clarithromycin alone, 200 mg/kg AZT plus 500 mg/kg clarithromycin, 400 mg/kg AZT plus 250 mg/kg clarithromycin, and 400 mg/kg AZT plus 500 mg/kg clarithromycin, and one female-B mouse in the control group was sacrificed in a moribund condition. None of these deaths were gavage accidents.

As with the female-A group, the majority of the clinical findings, other than piloerection and pallor, occurred in female-B mice that died prior to scheduled sacrifice. During the gestation period, piloerection occurred in 11 female-B mice treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin and in one, nine, and eight female-B mice, respectively, treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin. During the lactation period, piloerection occurred in seven mice treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin and three treated 400 mg/kg AZT plus 500 mg/kg clarithromycin. During the gestation period, pallor, believed to be a reflection of anemia, occurred in seven, eight, and seven female-B mice treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, respectively. During the lactation period, pallor occurred in one, three, and one females treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin and with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin, respectively. Other clinical findings occurring with low incidences were sunken eyes, decreased motor activity, cold to the touch, and labored breathing. These findings were not considered related to either test article because most were single nondosage-dependent events.

## Body Weights and Organ Weights

### Male Mice

Administration of 200 or 400 mg/kg AZT alone or 250, 500, or 1,000 mg/kg clarithromycin alone did not affect body weight or body weight gains (Figure 1 and Table A1). Administration of 200 or 400 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin had no effect on body weight or body weight gains. The slight significant (P≤0.05) elevation in terminal body weights of male mice (Table A2) treated with 400 mg/kg AZT plus 250 mg/kg clarithromycin was not considered to be biologically significant as the elevation was minor, and a dose-related pattern was not evident.

A significant elevation (P≤0.05) in the mean absolute liver weight (Figure 4 and Table A2) occurred in males treated with 1,000 mg/kg clarithromycin alone. This minor elevation was not considered to be biologically significant, as a dose-related pattern did not occur, and corresponding elevations in clinical chemistry parameters indicative of liver toxicity did not occur. Treatment with 200 or 400 mg/kg AZT alone or in combination with 250, 500, or 1,000 mg/kg clarithromycin had no impact on liver weights of male mice.

### Female-A Mice

Reduced body weight gains (Figure 2 and Table A1) occurred in the female-A groups treated with 200 (P≤0.05) or 400 (P≤0.01) mg/kg AZT alone, 1,000 mg/kg clarithromycin alone, 200 mg/kg AZT in combination with 250, 500 (P≤0.01), or 1,000 (P≤0.01) mg/kg clarithromycin, and 400 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin (P≤0.01 in all groups). In general, the reduced body weights corresponded with reduced gravid uterine weights as significant declines (P≤0.05) in mean corrected body weights (terminal body weight minus gravid uterine weight) did not occur.

Significant declines (P≤0.05) in absolute liver weights occurred in female-A groups treated with 400 mg/kg AZT alone and in the groups treated with 400 mg/kg AZT in combination with 250 or 500 mg/kg clarithromycin (Figure 4 and Table A2). Relative liver weights, which take body weights into consideration, were lower (P≤0.05) in the groups treated with 400 mg/kg AZT alone and 400 mg/kg AZT plus 500 mg/kg clarithromycin. These slight declines in liver weights were not considered to be a reflection of liver toxicity but tended to parallel slight declines in corresponding body weights.

### Female-B Mice

Slight reductions in average body weight gains and body weights occurred in female-B groups treated with 200 mg/kg AZT in combination with 500 or 1,000 mg/kg clarithromycin and in the groups treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin (Figure 3 and Table A1). The decline in average body weight was significant (p≤0.05) in the group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. A similar pattern of reduced body weight gains occurred during gestation and lactation periods. In general, the more severely affected groups also had reductions in live litter size or no live litters (400 mg/kg AZT plus 1,000 mg/kg clarithromycin).

FIGURE 1 Mean Body Weights of Male Swiss (CD-1® Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

(TSAC = Terminal Sacrifice)

FIGURE 2 Mean Body Weights of Female-A Swiss (CD-1® Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Plots A, C, and E show body weights from day 0 through terminal sacrifice (TSAC). Plots B, D, and F show the identical data except body weights at TSAC are after gravid uterine weights have been subtracted. Group mean body weights include only values for dams that were actually pregnant and were sacrificed and caesarean-sectioned as scheduled on presumed day 19 of gestation.]

FIGURE 3 Mean Body Weights of Female-B Swiss (CD-1® Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

(GD = Gestation Day; LD =Lactation Day. Gestation period body weights include only dams that were actually pregnant; lactation period body weights include only dams that delivered litters and had surviving pups.)

(GD = Gestation Day; LD = Lactation Day, *no litters were delivered in the 400 + 1,000 mg/kg group. Gestation period body weights include only dams that were actually pregnant; lactation period body weights include only dams that delivered litters and had surviving pups.)

FIGURE 4 Mean Absolute Liver Weights for Male and Female-A Swiss (CD-1® Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, * = significantly different (P<0.05) from control group using the Student’s t-test.]

## Clinical Pathology

### Hematology

#### AZT Alone

Administration of AZT alone caused mild declines in red blood cell (RBC), hemoglobin (Hgb), and hematocrit (Hct) values and mild to moderate increases in mean cell volume (MCV) and red cell distribution width (RDW) in both male and female mice. Mean RBC counts for mice (Figure 5 and Table B1) treated with 200 or 400 mg/kg AZT were, respectively, 10% (9.29 × 10^6^/μL) and 23% (7.95 × 10^6^/μL, P<0.01) lower in males, and 11% (7.60 × 10^6^/μL) and 10% (7.75 × 10^6^/μL) lower in female-A mice than the mean RBC counts in the respective control groups (10.34 and 8.57 × 10^6^/μL). In general, declines in Hgb and Hct values (Table B1) paralleled the declines in RBC counts. For female-B mice treated for approximately 10 days, slight declines in mean RBC counts occurred (Table B1); however, the changes were too minimal to be considered biologically significant.

The declines in RBC counts in male and female-A mice treated with AZT alone were accompanied by mild to moderate macrocytosis and increased RDW values, changes indicative of increased anisocytosis of erythrocytes. In general, the macrocytosis was most evident in female-A mice treated for approximately 30 days, slightly less severe in males treated for approximately 20 days, and least evident in female-B mice treated for approximately 10 days. MCV values for female-A mice (Figure 6 and Table B1) treated with 200 or 400 mg/kg AZT were both approximately 13% (55.5 fL and 55.3 fL, P&003C;0.01) greater than that in the control group (49.0 fL). In male mice treated with the same dosages, MCV values were approximately 8%(50.3 fL, P<0.05) and 13% (52.4 fL, P<0.01) greater than that (46.5 fL) in the control group. Female-B mice had respective MCV values approximately 5% (54.4 fL, P<0.01) and 6% (54.7 fL, P<0.01) greater than that (51.6 fL) in the control group. Elevations in mean cell hemoglobin (MCH) values paralleled the elevations in MCV values in both sexes. Reticulocytosis did not accompany the macrocytosis in any of the AZT treatment groups.

A treatment-related increase in RDW values, indicative of anisocytosis, occurred and, in general, males and female-A mice had the greatest increases and female-B mice had the smallest increases. Respective mean RDW values for female-A mice (Figure 7 and Table B1) treated with 200 or 400 mg/kg AZT were approximately 1.2 fold (19.9%) and 1.3 fold (21.1%, P<0.05) greater than the mean (16.0%) in the controls. Male mice treated with identical dosages had mean RDW values approximately 1.4 fold (19.8%, P<0.01) and 1.6 fold (22.3%, P<0.01) greater than the control group mean (13.9%). Respective mean RDW values for female-B mice (Table B1) treated with 200 and 400 mg/kg AZT were approximately 1.2 fold (19.9%, P<0.01) and 1.3 fold (21.4%, P<0.01) greater than the control group mean (17.1%).

No consistent treatment-related changes occurred in leukocyte or platelet parameters subsequent to administration of 200 or 400 mg/kg AZT (Table B1). The slight, but minimal, lymphocytosis (5.21 × 10^3^/μL, P<0.05) in female-A mice treated with 400 mg/kg AZT was not considered treatment related because the response was not dose related.

The dysplastic changes in erythrocytes (elevated RDW and MCV values in the absence of reticulocytosis) that accompanied the slight treatment-related anemia indicate that mild treatment-related erythropoietic toxicity occurred. The slight nonregenerative macrocytic anemia is compatible with results reported in B6C3F_1_ mice (Thompson, et al., 1991). The greater effects in female-A mice likely reflect the longer duration of treatment (approximately 30 days) when compared to males (approximately 20 days) and females-B (approximately 10 days). The alterations in erythrocytes indicate that increased RBC turnover occurred, which is compatible with the increased hematopoietic cell proliferation and hemosiderosis found microscopically in the spleens of male and female-A mice.

#### Clarithromycin Alone

Administration of 250, 500, or 1,000 mg/kg clarithromycin alone to male and female mice did not result in consistent changes in erythrocyte parameters (Table B1). A leukocytosis occurred in the female-A mice treated with 1,000 mg/kg clarithromycin; the mean WBC count was approximately 2.2 fold (12.74 x 10^3^/μL, P<0.01) greater than the mean in the control group (5.92 x 1 0^3^/μL). Evaluation of the differential data revealed significant increases in neutrophils (Figure 10 and Table B1) and lymphocytes, with respective values approximately 3.3 fold (5.71 x 10^3^/μL, P<0.01) and 1.5 fold (5.89 x 10^3^/μL, P<0.01) greater than those of the control group (1.71 and 3.92 x 10^3^/μL). Significant alterations in leukocyte counts did not occur in male or female-B mice treated with clarithromycin alone (Table B1).

#### AZT and Clarithromycin Combinations

AZT in combination with clarithromycin resulted in a treatment-related anemia of far greater severity than the anemia that occurred with AZT alone. In general, the severity of the hematological changes was greatest in female-A mice treated for approximately 30 days, less in male mice treated for approximately 20 days, and least prominent in female-B mice treated for approximately 10 days. Combination therapy also caused macrocytosis and microcytosis, increases in RDW values, reticulocytopenia, leukocytosis and leukopenia, neutrophilia, lymphopenia, and thrombocytosis.

Respective mean RBC counts in female-A mice treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin (Figure 5 and Table B1) were approximately 23% (6.59 x 10^6^/μL, P<0.01), 22% (6.66 x 10^6^/μL, P<0.01), and 30% (6.01 x 10^6^/μL, P<0.01) lower than the mean (8.57 x 10^6^/μL) in the control group. For the female-A groups treated with 400 mg/kg AZT plus the same dosages of clarithromycin, respective mean RBC counts were approximately 39% (5.22 x 10^6^/μL, P<0.01), 71 % (2.45 x 10^6^/μL, P<0.01), and 57% (3.66 x 10^6^/μL, P<0.01) lower than the control mean (8.57 x 10^6^/μL). The anemia was less severe in male groups treated with AZT and clarithromycin combinations for approximately 20 days than in female-A groups treated for approximately 30 days. Respective mean RBC counts in males treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin were approximately 33% (6.94 x 10^6^/μL, P<0.01), 32% (7.02 x 10^6^/J1L, P<0.01), and 42% (5.95 x 10^6^/μL, P<0.01) lower than the control mean (10.34 x 10^6^/μL). In general, Hgb and Hct values paralleled the changes in RBC counts. Significant (p<0.05) alterations in RBC, Hgb, and Hct values did not occur in female-B mice receiving combination therapy for approximately 10 days.

In general, the anemia that occurred with combination therapy was accompanied by erythrocytic macrocytosis in lower-dose combination groups and reversal of this change toward normocytic or microcytic anemia at higher dose combination levels. Respective MCV values for female-A mice (Figure 6 and Table B1) treated with 200 mg/kg AZT plus 250,500, or 1,000 mg/kg clarithromycin were approximately 18% (57.6 fL, P<0.01), 22% (59.7 fL, P<0.01), and 8% (53.0 fL) greater than the mean (49.0 fL) in the control group. Female-A mice treated with 400 mg/kg AZT plus the same dosages of clarithromycin had respective MCV values approximately 9% higher (53.6 fL, P<0.05), 9% lower (44.5 fL), and 4% lower (46.8 fL) than the control mean. Respective MCV values for males treated with 200 mg/kg AZT plus 250,500, or 1,000 mg/kg clarithromycin were approximately 10% (51.0 fL, P<0.01), 9% (50.6 fL, P<0.01), and 5% (48.9 fL)higher than the control mean (46.5 fL). Males treated with 400 mg/kg AZT plus the same dosages of clarithromycin had respective MCV values approximately 9% (50.6 fL, P<0.05), 7% (49.7 fL), and 2% (47.5 fL) higher than the control mean. In female-B groups treated with combinations for approximately 10 days, MCV values ranged from 4% (53.7 fL) for the 400 mg/kg AZT plus 250 mg/kg clarithromycin group to 7% (55.4 fL, P<0.01) for the with 200 mg/kg AZT plus 500 mg/kg clarithromycin group, greater than the mean (51.6 fL) in the controls. In general, the calculated MCH values tended to parallel MCV values in all dosage groups for both sexes.

Anisocytosis, measured by increased RDW values, occurred in males and females given combination therapy. As with MCV values, greater increases in RDW values tended to occur in groups treated with lower dose combinations. Respective mean RDW values in female-A groups (Figure 7 and Table B1) treated with 200 mg/kg AZT plus 250,500, or 1,000 mg/kg clarithromycin were approximately 1.6 fold (25.8%, P<0.01), 1.6 fold (26.7%, P<0.01), and 1.5 fold(24.6%,P<0.01) greater than the mean (16.0 %) in the control group. The mean RDW value in the female-A group treated with 400 mg/kg AZT plus 250 mg/kg clarithromycin was approximately 1.6 fold (25.4%, P<0.01) greater than the control mean. Significant alterations (p<0.05) in RDW values did not occur in female-A groups treated with 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin. Respective mean RDW values for males treated with 200 mg/kg AZT plus 250,500, or 1,000 mg/kg clarithromycin were approximately 1.6 fold (21.7%, P<0.01), 1.7 fold (23.1%, P<0.01), and 1.5 fold (21.5%, P<0.01) greater than the control mean (13.9%). For males treated with 400 mg/kg AZT plus the same dosages of clarithromycin, respective mean RDW values were approximately 1.7 fold (24.2%, P<0.01), 1.7 fold (24.2%, P<0.01), and 1.6 fold (21.7%, P<0.01) greater than the control mean. Milder elevations in RDW values occurred in all female-B groups treated with combination therapy, with values 1.3 to l.4fold(22.0%,P<0.01, to 23.9%, P<0.01) greater than the mean (17.1%) in the control group.

Reticulocytopenia accompanied the treatment-related anemia in the higher-dose female-A combination groups. Respective mean reticulocyte counts in female-A groups treated with 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin (Figure 8 and Table B1) were approximately 85% (0.6 x 10^5^/μL, P<0.01) and 51% (1.9 x 10^5^/μL) lower than the mean (3.9 x 10^5^/μL) in the control group. Significant alterations (p<0.05) in reticulocyte counts did not occur in male or female-B mice. There was no instance in which significant elevations (p<0.05) in reticulocyte counts accompanied the significant (p<0.05) macrocytosis or increased RDW values.

Thrombocytosis occurred in male and female-A mice treated with combination therapy. Respective mean platelet counts for female-A mice (Figure 9 and Table B1) treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin were approximately 1.4 fold (1,442 × 10^3^/μL, P<0.01), 1.3 fold (1,332 × 10^3^/μL), and 1.3 fold (1,386 × 10^3^/μL, P<0.05) greater than the mean (1,034 × 10^3^/μL) in the control group. For the female-A groups treated with 400 mg/kg AZT and 250, 500, or 1,000 mg/kg clarithromycin, respective mean platelet counts were approximately 1.7 fold (1,750 × 10^3^/μL, P<0.01), 1.9 fold (1,982 × 10^3^/μL, P<0.01),and 1.6 fold (1,645 × 10^3^/μL, P<0.01) higher than the control mean. Although not statistically significant, platelet counts in male mice treated with combination therapy ranged from 1.3 fold (1,095 × 10^3^/μL) in the 200 mg/kg AZT plus 500 mg/kg clarithromycin group, to 1.7 fold (1,412 × 10^3^/μL) in the 400 mg/kg AZT plus 500 mg/kg clarithromycin group, greater than the mean (838 × 10^3^/μL) for the controls. Biologically significant alterations in platelet counts did not occur in female-B mice.

Significant (p<0.05) alterations in leukocyte values (Table B1) did not occur in any of the male or female groups treated with combinations of AZT and clarithromycin.

FIGURE 5 Mean Red Blood Cell Values for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, ** = significantly different (P<0.01) from control group using Dunnett’s procedure.]

FIGURE 6 Mean Mean Corpuscular Volume for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, * = significantly different (P<0.05) from control group using Dunnett’s procedure, ** = significantly different (P<0.01) from control group using Dunnett’s procedure.]

FIGURE 7 Mean Red Cell Distribution Width of Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, * = significantly different (p<0.05) from control group using Dunnett’s procedure, ** = significantly different (p<0.01) from control group using Dunnett’s procedure.]

FIGURE 8 Mean Reticulocyte Values for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, ** = significantly different (P<0.01) from control group using Dunnett’s procedure.]

FIGURE 9 Mean Platelet Values for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, * = significantly different (P<0.05) from the control group using Dunnett’s procedure, ** = significantly different (P<0.01) from control group using Dunnett’s procedure.]

FIGURE 10 Mean Segmented Neutrophil Values for Male and Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

[Bars indicate standard deviation, ** = significantly different (P<0.01) from control group using Dunnett’s procedure.]

### Clinical Chemistry

#### AZT Alone

Administration of 200 or 400 mg/kg AZT to male and female-A mice did not result in any treatment-related changes in serum chemistry parameters (Table B2).

#### Clarithromycin Alone

Administration of 250 or 500 mg/kg clarithromycin alone to male and female-A mice was not associated with any treatment-related alterations in any of the clinical chemistry parameters (Table B2). Significant alterations (P<0.05) in clinical chemistry parameters did not occur in the male group treated with 1,000 mg/kg clarithromycin for approximately 20 days. For the female-A group treated with 1,000 mg/kg clarithromycin for approximately 30 days, a slight increase in blood urea nitrogen (BUN) and alanine aminotransferase (ALT) values occurred. When compared to the female-A control group, with a BUN value of 18.3 mg/dL, the 1.3-fold increase (23.5 mg/dL, P<0.01) in the BUN value in the 1,000 mg/kg group was not believed to be biologically significant because a corresponding increase (P<0.05) in the creatinine value did not occur. Similarly, the 1.4-fold increase (52 U/L, P<0.05) in the ALT value in the 1,000 mg/kg female-A group, compared to 36 U/L in the control group, was not accompanied by increases in alkaline phosphatase, aspartate aminotransferase, or bile acid values indicative of liver toxicity.

#### AZT and Clarithromycin Combinations

Increases in clinical chemistry parameters (Table B2) indicative of kidney and liver toxicity did not occur in male or female-A mice treated with 200 or 400 mg/kg AZT in combination with 250, 500, or 1,000 mg/kg clarithromycin. Respective mean BUN values for female-A groups treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin were approximately 1.3 fold (24.2 mg/dL, P<0.01), 1.5 fold (27.8 mg/dL, P<0.01), and 1.3 fold (24.4 mg/dL, P<0.05) greater than the mean control value (18.3 mg/dL). These mild elevations in BUN values were not believed to be indicative of renal toxicity because corresponding elevations (p<0.05) in creatinine values did not occur. The statistically significant decrease (p<0.05) in ALT activity in the female-A group treated with 400 mg/kg AZT plus 500 mg/kg clarithromycin was not considered biologically significant.

## Plasma Concentrations of AZT and Clarithromycin

### AZT

A summary of plasma concentrations of AZT and its metabolites β-D-glucuronide of AZT (GAZT) and 3'-amino-3'-deoxythymidine (AMT) at 30, 60, 120, and 240 minutes after the last gavage dose is presented in Table 2 for male mice and in Table 3 for the pregnant female-A mice. The values for male mice are means of two samples from two different mice and those for females are means of up to three samples from up to three different mice at each time point.

#### Male Mice

Administration of 400 mg/kg AZT alone resulted in plasma AZT concentrations of 141.5 to 0.96 μg/mL, GAZT concentrations of 4.16 μg/mL to nondetectable (ND, < 0.2 μg/mL) levels, and AMT concentrations of 1.32 μg/mL to nondetectable levels. Administration of 400 mg/kg AZT and 250 mg/kg clarithromycin resulted in plasma AZT concentrations of 48.0 to 2.3 μg/mL, GAZT concentrations of 1.10 μg/mL to nondetectable levels, and AMT concentrations of 0.60 to 0.23 μg/mL. Administration of 400 mg/kg AZT and 500 mg/kg clarithromycin resulted in plasma AZT concentrations of 31.0 to 2.6 μg/mL, GAZT concentrations of 0.61 μg/mL to nondetectable levels, and AMT concentrations of 0.57 to 0.16 μg/ml. The highest dose combination, 400 mg/kg AZT and 1,000 mg/kg clarithromycin resulted in plasma AZT concentrations of 13.2 to 3.3 μg/mL, GAZT concentrations of 0.32 μg/mL to nondetectable levels, and AMT concentrations of 0.3 7 to 0.25 μg/mL from 30 to 240 minutes after the last dose in mice previously treated daily for approximately 20 days. The plasma 3’ -amino-3’ -deoxythymidine glucuronide (GAMT) concentrations in the male samples were at less than the detectable levels («0.2μg/mL). Peak plasma concentrations of AZT in male mice decreased as the dose of clarithromycin increased, which is similar to the drug interaction previously described in acquired immunodeficiency syndrome patients treated simultaneously with AZT and clarithromycin (Polis et al., 1997).

#### Female-A Mice

Administration of 400 mg/kg AZT resulted in plasma AZT concentrations of 101.5 to 3.2 μg/mL, GAZT concentrations of 1.05 μg/mL to nondetectable levels, and AMT concentrations of 1.65 to 0.40 μg/mL. Oral administration of 400 mg/kg AZT and 250 mg/kg clarithromycin resulted in plasma AZT concentrations of 70.0 to 3.8 μg/mL, GAZT concentrations of 0.62 μg/mL to nondetectable levels, and AMT concentrations of 1.31 to 0.48 μg/mL. Administration of 400 mg/kg AZT and 500 mg/kg clarithromycin resulted in plasma AZT concentrations of 56.1 to 6.5 μg/mL, GAZT concentrations of 0.51 μg/mL to nondetetable levels, and AMT concentrations of 0.72 to 0.24 μg/mL. The highest dose combination of 400 mg/kg AZT and 1,000 mg/kg clarithromycin resulted in plasma AZT concentrations of 41. 7 to 4.1 μg/mL, GAZT concentrations of 0.41 μg/mL to nondetectable levels, and AMT concentrations of 0.81 to 0.41 μg/mL from 30 to 240 minutes after the last dose in mice previously treated daily for approximately 30 days. The plasma GAMT concentrations in the female-A samples were at less than the detectable levels. As in the male mice, peak plasma concentrations of AZT in female-A mice decreased as the oral dose of clarithromycin increased; however, plasma levels in general were higher in females than in males.

### Clarithromycin

A summary of plasma concentrations of clarithromycin at 30, 60, 120, and 240 minutes after gavage administration of the last dose is presented in Table 2 for male mice and in Table 3 for pregnant female-A mice.

#### Male Mice

Clarithromycin alone at 250 mg/kg per day resulted in plasma clarithromycin concentrations of 2.74 to 1.30 μg/mL. Administration in of 400 mg/kg AZT and 250 mg/kg clarithromycin resulted in plasma clarithromycin concentrations of 3.43 to 1.92 μg/mL. Clarithromycin alone at 500 mg/kg resulted in plasma clarithromycin concentrations of 2.32 to 1.39 μg/mL, and 500 mg/kg combined with 400 mg/kg AZT resulted in plasma clarithromycin concentrations of 2.61 to 1.94 μg/mL. Clarithromycin at 1,000 mg/kg resulted in plasma concentrations of 4.34 to 1.6 μg/mL, and this amount of clarithromycin with 400 mg/kg AZT resulted in plasma clarithromycin concentrations of 4.77 to 1.81 μg/mL from 30 to 240 minutes after gavage administration of the last dose to mice previously treated daily for approximately 20 days.

#### Female-A Mice

Oral administration of clarithromycin alone at 250 mg/kg resulted in plasma clarithromycin concentrations of 15.6 to 10.31 μg/mL. Administration of 400 mg/kg AZT and 250 mg/kg clarithromycin resulted in plasma clarithromycin concentrations of 19.35 to 10.94 μg/mL. Clarithromycin at 500 mg/kg resulted in plasma clarithromycin concentrations of 13.72 to 9.3 5 μg/ml, and 500 mg/kg combined with 400 mg/kg AZT resulted in plasma clarithromycin concentrations of 19.65 to 16.2 μg/mL. Clarithromycin at 1,000 mg/kg resulted in plasma concentrations of 17.60 to 9.48 μg/mL, and 1,000 mg/kg with 400 mg/kg AZT resulted in plasma clarithromycin concentrations of 21.2 to 4.8 μg/mL from 30 to 240 minutes after gavage administration of the last dose to pregnant mice previously treated daily for approximately 30 days. In general, plasma concentrations of clarithromycin were higher in female-A mice than in male mice after oral dosing with clarithromycin alone or clarithromycin in combination with AZT.

TABLE 2 Concentrations of AZT, AZT Metabolites, and Clarithromycin in Plasma Samples of Male Swiss (CD-1®) Mice Treated with AZT and/or Clarithromycin for Approximately 20 Days^a^

Dose^b^ | Sampling Time^c^ (minutes) | AZT (μg/mL) | GAZT^d^ (μg/mL) | AMT^e^ (μg/mL) | Clarithromycin (μg/mL)
400 + 0 | 30 | 141 5 | 4 16 | 1 32 | NA
| 60 | 19 8 | 0 35 | 0 51 | NA
| 120 | 19 6 | 0 30 | 1 06 | NA
| 240 | 0 96 | ND | 0 16 | NA
0 + 250 | 30 | NA | NA | NA | 1 30
| 60 | NA | NA | NA | 1 65
| 120 | NA | NA | NA | 2 74
| 240 | NA | NA | NA | 2 63
0 + 500 | 30 | NA | NA | NA | 146
| 60 | NA | NA | NA | 139
| 120 | NA | NA | NA | 2 32
| 240 | NA | NA | NA | 1 90
0+1,000 | 30 | NA | NA | NA | 2 96
| 60 | NA | NA | NA | 1 60
| 120 | NA | NA | NA | 2 34
| 240 | NA | NA | NA | 4 34
400 + 250 | 30 | 48 0 | 1 10 | 0 60 | 1 96
| 60 | 15 8 | 0 30 | 0 40 | 2 50
| 120 | 10 7 | 0 30 | 0 23 | 3 43
| 240 | 2 3 | ND | 0 60 | 1 92
400 + 500 | 30 | 31 0 | 0 61 | 0 57 | 2 61
| 60 | 13 5 | 0 13 | 0 28 | 1 98
| 120 | 6 3 | 0 11 | 0 16 | 1 94
| 240 | 2 6 | ND | 0 34 | 2 48
400+ 1,000 | 30 | 13 2 | 0 19 | 0 25 | 1 81
| 60 | 16 9 | 0 32 | 0 30 | 4 26
| 120 | 3 3 | ND | 0 34 | 3 33
| 240 | 5 1 | ND | 0 37 | 4 77

NA = not applicable, ND = not detected

a Mean of samples from two mice

b AZT + clarithromycin in mg/kg per day

c Minutes after the last dose

d β-D-glucuronide of AZT

e 3 -Ammo-3 -deoxythymidine

TABLE 3 Concentrations of AZT, AZT Metabolites, and Clarithromycin in Plasma Samples of Female Swiss (CD-1®) Mice Treated with AZT and/or Clarithromycin for Approximately 30 Days Before and During Pregnancy^a^

Dose^b^ | Sampling Time^c^ (minutes) | AZT (μg/mL) | GAZT^d^ (μg/mL) | AMT^e^ (μg/mL) | Clarithromycin (μg/mL)
400 + 0 | 30 | 101 5 | 1 05 | 0 82 | NA
| 60 | 29 8 | 0 35 | 0 40 | NA
| 120 | 13 7 | ND | 0 76 | NA
| 240 | 3 2 | ND | 1 65 | NA
0 + 250 | 30 | NA | NA | NA | 14 60
| 60 | NA | NA | NA | 10 97
| 120 | NA | NA | NA | 15 60
| 240 | NA | NA | NA | 10 31
0+500 | 30 | NA | NA | NA | 13 02
| 60 | NA | NA | NA | 11 90
| 120 | NA | NA | NA | 9 35
| 240 | NA | NA | NA | 13 72
0+1,000 | 30 | NA | NA | NA | 12 35
| 60 | NA | NA | NA | 15 30
| 120 | NA | NA | NA | 17 60
| 240 | NA | NA | NA | 9 48
400 + 250 | 30 | 70 0 | 0 62 | 1 03 | 14 80
| 60 | 36 2 | 0 31 | 0 50 | 12 30
| 120 | 6 2 | ND | 0 48 | 19 35
| 240 | 3 8 | ND | 1 31 | 10 94
400 + 500 | 30 | 56 1 | 0 51 | 0 61 | 16 70
| 60 | 34 7 | 0 33 | 0 72 | 19 65
| 120 | 7 7 | ND | 0 24 | 18 50
| 240 | 6 5 | ND | 0 68 | 16 20
400+ 1,000 | 30 | 41 7 | 0 33 | 0 49 | 6 45
| 60 | 34 6 | 0 41 | 0 41 | 4 80
| 120 | 13 6 | ND | 0 44 | 21 20
| 240 | 4 1 | ND | 0 81 | 19 70

NA = not applicable, ND = not detected

a Mean of samples from one to three mice

b AZT + clarithromycin in mg/kg per day

c Minutes after the last dose

d β-D-glucuronide of AZT

e 3 -Ammo-3 -deoxythymidine

## Necropsy Findings

Necropsy findings attributed to treatment with one or both drugs were seen in male mice, female-A mice, and female-B mice (Table C1). Necropsy findings in male mice that appeared to be treatment related consisted of pale carcass, mottled or pale kidneys, and small thymus. Possible treatment-related findings in female-A mice were small thymus, enlarged spleen, mottled or pale kidneys, pale carcass, dilatation of the stomach, and mottled stomach. The most significant finding in female-B mice was enlarged spleen. Deformed bone, including the ventral aspect of the thoracic vertebrae or ribs near their junction, occurred randomly in all groups and was attributed to mechanical irritation caused by the gavage needle during dosing.

## Histopathologic Observations

Major target organs included the liver, spleen, bone marrow, kidney, lymph nodes, thymus, brain, and heart. Selected photomicrographs of bone marrow from a control mouse and a treated mouse are shown in Plates 1 and 2.

### Male and Female-A Mice

#### Liver Lesions

Male and female-A mice treated with AZT alone, clarithromycin alone, or combinations of AZT and clarithromycin developed cytoplasmic alteration in the liver (Table 4). This cellular change consisted of a more homogeneous, eosinophilic appearance to the hepatocyte cytoplasm accompanied by a concurrent loss of the fine irregularly shaped clear spaces normally attributed to the presence of glycogen in routine hematoxylin and eosin (H&E) preparations. There was also an absence of round, clear cytoplasmic vacuoles normally attributed to the presence of fat. This morphological alteration evident in the cytoplasm of hepatocytes likely represents a physiological response associated with weight loss, as opposed to a direct toxic cellular response to the test articles. The morphological change appeared to initially occur in the centrilobular areas adjacent to the central veins and subsequently involve the remaining zones of the liver lobule. Hepatocellular cytoplasmic alteration was graded for severity using the following criteria:

- Minimal severity - approximately 10% or less of hepatocytes, predominately around the central vein, with cytoplasmic alteration
- Mild severity - approximately 11% to 25% of hepatocytes with cytoplasmic alteration, possibly involving all zones of the lobule. This degree of severity was usually accompanied by other more significant changes such as cytoplasmic vacuolization or necrosis.

For male and female-A mice treated with AZT alone, the incidence of hepatocellular cytoplasmic alteration was low, and the degree of severity was considered minimal in all dose groups of both sexes. This liver lesion was not associated with any significant alterations in any of the clinical pathology parameters and was not statistically significant. For the male groups treated with AZT and clarithromycin combinations, the incidence was low, and significant increases (P<0.05) in severity grades did not occur (Table 5). Compared to the untreated control group, a significant (P<0.01) increase in severity occurred in the female-A group treated with 1,000 mg/kg clarithromycin alone. Compared to the groups treated with fixed levels of AZT alone (200 or 400 mg/kg), significant (P<0.01) increases in severity grades occurred in female-A groups receiving 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin and 400 mg/kg AZT plus 250,500, or 1,000 mg/kg clarithromycin. The greater incidence of hepatocellular cytoplasmic alteration in female-A mice compared to the males corresponds with the increased duration of treatment.

A lesion in the liver of male and female-A mice associated with the highest dose of clarithromycin was cytoplasmic vacuolization (Table 4). The cytoplasmic vacuoles appeared to be largest and most prominent in the Kupffer cells, but also occurred to a lesser degree in the cytoplasm of hepatocytes. Cytoplasmic vacuolization of the liver was graded based on the following criteria:

- Minimal severity - utilizing a 4x objective and a 10x eyepiece, occasional vacuoles, approximately the same size as the hepatocyte nuclei, were found randomly distributed throughout the liver. Cytoplasmic vacuoles were present in approximately 10% or less of Kupffer cells
- Mild severity - utilizing a 4x objective and a 10x eyepiece, cytoplasmic vacuolization was evident in essentially all liver lobules. Irregular-shaped, clear spaces typical of glycogen in hepatocyte cytoplasm were replaced by round, clear cytoplasmic vacuoles. Cytoplasmic vacuoles were present in approximately 11% to 25% of Kupffer cells
- Moderate severity - utilizing a 4x objective and a 10x eyepiece, cytoplasmic vacuolization was uniformly present in all liver lobules. Irregular-shaped spaces typical of glycogen in the hepatocyte cytoplasm were replaced by round, clear cytoplasmic vacuoles. Cytoplasmic vacuoles were present in approximately 26% to 50% of the Kupffer cells.

The incidence of cytoplasmic vacuolization was similar in male and female-A mice. The lesion did not occur in groups treated with 250 or 500 mg/kg clarithromycin alone or in combination with AZT. Cytoplasmic vacuolization occurred with a low incidence in female-A mice treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin and in male and female-A groups treated with 1,000 mg/kg clarithromycin alone and 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. Combination therapy did not appear to enhance the incidence or severity of cytoplasmic vacuolization in the liver.

Treatment-related necrosis of hepatocytes (Table 4) also occurred in female-A mice treated with 1,000 mg/kg clarithromycin alone or in combination with AZT. The cellular necrosis was manifested by increased eosinophilia of disrupted cytoplasm and karyorrhexis and pyknosis of nuclear material. The necrosis occurred in a zonal pattern predominately around the central veins. Criteria for the grading of hepatocyte necrosis were as follows:

- Minimal severity - occasional («10%) necrotic cells present in a centrilobular pattern
- Mild severity - approximately 11% to 25% of hepatocytes in centrilobular areas undergoing necrosis.

Hepatocyte necrosis of minimal severity occurred in two female-A mice treated with 1,000 mg/kg clarithromycin alone and in three female-A mice each in the groups treated with 200 or 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. Necrosis was not diagnosed in any of the male mice treated with combinations of AZT and clarithromycin or in the female-A groups treated with AZT in combination with 250 or 500 mg/kg clarithromycin. The minimal necrosis of hepatocytes may reflect an anoxic change secondary to anemia.

TABLE 4 Histopathological Alterations in the Liver in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Cytoplasmic Alteration^b^ | | Necrosis^b^ | | Cytoplasmic Vacuolization^b^
Dose^a^ | Males | Females-A | Males | Females-A | Males | Females-A
0 + 0 | 0/10 | 0/20 | 0/10 | 0/20 | 0/0 | 0/20
0 + 250 | 0/10 | 3/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
0 + 500 | 3/10 (1 0) | 2/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
0 + 1,000 | 2/10 (1 0) | 10/20 (13) | 0/10 | 2/20 (10) | 1/10 (10) | 2/20 (2 5)
200 + 0 | 3/10 (1 0) | 1/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
200 + 250 | 6/10 (1 0) | 8/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
200 + 500 | 3/10 (1 0) | 16/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
200+ 1,000 | 2/10 (1 0) | 18/20 (1 1) | 0/10 | 3/20 (1 0) | 0/10 | 3/20 (1 0)
400 + 0 | 2/10 (1 0) | 2/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
400 + 250 | 1/10 (2 0) | 13/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
400 + 500 | 4/10 (1 3) | 20/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
400+ 1,000 | 4/10 (10) | 19/20 (1 1) | 0/10 | 3/20 (1 0) | 1/10 (10) | 2/20 (1 0)

a AZT + clarithromycin in mg/kg per day

b Number of animals in group with lesion/number of animals examined (mean seventy for mice with lesion, grade l=minimal, 2=mild, 3=moderate, 4=marked)

TABLE 5 Statistical Analysis of Mean Severity of Hepatocellular Cytoplasmic Alteration in Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Clarithromycin Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females-A^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^e^ | Mean^d^ | S.E. | Ratio^e^
0 + 0 | 0 000 | 0 000 | NA | 0 000 | 0 000 | NA
0 + 250 | 0 000 | 0 000 | — | 0 150 | 0 082 | —
0 + 500 | 0 300 | 0 153 | — | 0 100 | 0 069 | —
0 + 1,000 | 0 200 | 0 133 | — | **0 650 | 0 182 | —
| Trend^f^ | + (P=0 057) | | Trend^f^ | + (P=0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley
200 + 0 | 0 300 | 0 153 | NA | 0 050 | 0 050 | NA
200 + 250 | 0 600 | 0 163 | 200 | 0 400 | 0 112 | 800
200 + 500 | 0 300 | 0 153 | 100 | **0 800 | 0 092 | 1,600
200+ 1,000 | 0 200 | 0 133 | 67 | **1 000 | 0 103 | 2,000
| Trend^f^ | - (P=0 380) | | Trend^f^ | + (P<0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley
400 + 0 | 0 200 | 0 133 | NA | 0 100 | 0 069 | NA
400 + 250 | 0 200 | 0 200 | 100 | **0 650 | 0 109 | 650
400 + 500 | 0 500 | 0 224 | 250 | **1 000 | 0 000 | 1,000
400 + 1,000 | 0 400 | 0 163 | 200 | **1 000 | 0 073 | 1,000
| Trend^f^ | + (P=0 198) | | Trend^g^ | + (P<0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley

a Seventy grade presented as mean seventy (l=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S E)

b AZT + clarithromycin in mg/kg per day

c n=10

d n=20

e (Dosed group mean /control group mean) x 100, NA = not applicable, — = ratio cannot be calculated

f Direction and significance of trend (Jonckheere’s test)

g Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P<0 05)

** Significantly different from the control group (P<0 01)

#### Spleen Lesions

A treatment-related alteration in the spleen of male and female-A mice (Table 6) treated with 200 or 400 mg/kg AZT consisted of hematopoietic cell proliferation evident in the red pulp. The hematopoiesis involved primarily cells of the erythroid and megakaryocytic series and was believed to have been a compensatory response to the slight anemia induced by AZT. Extramedullary hematopoiesis (grade 0 for hematopoietic cell proliferation) consisting of megakaryocytes, foci of erythroid precursors, and large granulocytic precursors is a normal occurrence in the red pulp of the spleen of mice (Maronpot, 1999). Hematopoietic cell proliferation of the spleen was graded for severity based on the following criteria:

- Minimal severity - utilizing a 4x objective and a 10x eye piece, the width of the spleen usually approached or slightly exceeded the field of view. Approximately 10% or less of the red pulp was occupied by erythropoietic cells and/or megakaryocytes
- Mild severity - utilizing a 4x objective and a 10x eye piece, the width of the spleen usually approached or slightly exceeded the field of view. Approximately 11% to 25% of the red pulp was occupied by erythropoietic cells and/or megakaryocytes
- Moderate severity - the width of the spleen exceeded the field of view when observed with a 4x objective and a 10x eyepiece. Approximately 26% to 50% of the red pulp was occupied by erythropoietic cells and/or megakaryocytes.

The incidence of hematopoietic cell proliferation in male mice increased as dose levels of AZT increased; however, the degree of severity was considered minimal for both treatment groups. For the female-A mice, the incidence and the severity increased slightly as AZT dose levels increased. For the male groups treated with 250 or 1,000 mg/kg clarithromycin alone, hematopoietic cell proliferation occurred with a low incidence; however, when compared to the untreated control group, a significant increase (P<0.05) in mean severity occurred in the male group treated with 1,000 mg/kg clarithromycin alone (Table 7). For the female-A groups treated with 250, 500, or 1,000 mg/kg clarithromycin, the incidence and severity of hematopoietic cell proliferation were slightly greater than for the control group. Statistically significant (p<0.05) increases in severity grades, however, did not occur. For the male groups treated with 200 mg/kg AZT plus clarithromycin, the incidence of hematopoietic cell proliferation was similar to the group treated with 200 mg/kg AZT alone. For male groups treated with 400 mg/kg AZT in combination with clarithromycin, the incidence of hematopoietic cell proliferation was lower than for the group treated with 400 mg/kg AZT alone. Statistically significant (p<0.05) alterations in severity grades, however, did not occur. For the female-A groups treated with 200 mg/kg AZT plus clarithromycin, the incidence of hematopoietic cell proliferation was greater than for the female-A group treated with 200 mg/kg AZT alone. Compared to the female-A group treated with 200 mg/kg AZT alone, significant increases (p<0.01) in severity grades occurred in groups treated with 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin. For the female-A groups treated with 400 mg/kg AZT in combination with clarithromycin, the incidence of hematopoietic cell proliferation decreased as dose levels of clarithromycin increased. Compared to the group treated with 400 mg/kg AZT alone, significant declines (p<0.0 1) in mean severity grades occurred in groups treated with 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin. The lower hematopoietic cell proliferation in the higher-dosed combination groups was believed to reflect an inability of the spleen to adequately respond to the anemia that occurred in these groups.

A slight increase in the amount of hemosiderin deposition in the red pulp of the spleen (Table 6) occurred in male and female-A mice treated with AZT alone. Hemosiderin deposition was believed to be associated with the hematological alterations evident in the peripheral blood and likely resulted from an increased turnover rate of RBCs. Hemosiderin deposition in the spleen was graded for severity based on the following criteria:

- Minimal severity - utilizing a 4x objective in conjunction with a 10x eyepiece, a faint brown tint was suspected in the red pulp of the spleen. Higher magnification revealed pigment deposition in up to approximately 10% of the macrophages in the red pulp
- Mild severity - utilizing a 4x objective in conjunction with a 10x eyepiece, a faint brown tint was present in the red pulp of the spleen. Higher magnification revealed pigment deposition in approximately 11% to 25% of the macrophages in the red pulp
- Moderate severity - a distinct brown to tan coloration was evident in the red pulp when viewed with a 4x objective and a 10x eyepiece. Higher magnification revealed pigment in approximately 26% to 50% or more of the macrophages in the splenic red pulp.

The presence of iron in the deposits of pigment was verified in representative animals from affected treatment groups by a positive staining reaction using a Prussian Blue stain (Sheehan and Rapchak, 1980). Increased hemosiderin pigmentation did not occur in male or female-A mice treated with clarithromycin alone. Combination therapy resulted in increased hemosiderin deposition in both sexes.

With dosages of 200 or 400 mg/kg AZT alone, the incidence of hemosiderin pigmentation in the spleen increased slightly in male and female-A mice as dose levels increased (Table 6). The degree of severity was graded as minimal to mild for all treatment groups of both sexes. Increased hemosiderin deposition did not occur in male or female-A groups treated with 250, 500, or 1,000 mg/kg clarithromycin alone (Table 6). For male and female-A mice treated with combination therapy, hemosiderin deposition in the spleen tended to increase as dose levels of AZT and clarithromycin increased and corresponded with the anemia indicated by the hematology parameters. Compared to the male group treated with 200 mg/kg AZT alone, a significant increase (P<0.01) in the severity occurred in the group treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin (Table 7). When compared to the groups treated with 200 or 400 mg/kg AZT alone, significant increases (p<0.01) in severity occurred in all female-A groups receiving combination therapy (Table 8).

Depletion of splenic lymphoid follicles and red pulp occurred in the female-A groups treated with 1,000 mg/kg clarithromycin and in the male and female-A groups treated with AZT plus higher dosages of clarithromycin (Table 6). Depletion of the red pulp involved primarily cells of the erythrocytic series and was often accompanied by reticuloendothelial cells with large clear vacuoles in their cytoplasm. The vacuoles were often so extensive that the spleen appeared larger than normal. At times, the swollen reticuloendothelial cells appeared to be associated with sequestration of polymorphonuclear leukocytes in the sinusoids of the spleen. In general, depletion of the red pulp usually occurred concurrently with cellular depletion of the white pulp or lymphoid follicles. Depletion of the red pulp and lymphoid follicles of the spleen was graded based on the following criteria:

- Minimal severity - depletion of approximately 10% or less of the normal cell population
- Mild severity - depletion of approximately 11% to 25% of the normal cell population with distinct vacuoles being evident in the red pulp when viewed with a 4x objective and a 10x eyepiece
- Moderate severity - depletion of approximately 26% to 50% of the normal cell population with distinct vacuoles being prominent in the red pulp when viewed with a 4x objective and a 10x eyepiece
- Marked severity - depletion of approximately 51% to 100% of the normal cell population and prominent vacuolated reticuloendothelial cells replacing the majority of the red pulp when viewed with a 4x objective and a 10x eyepiece.

Atrophy of the splenic red pulp and lymphoid follicles (Table 6) occurred with a low incidence in the female-A group treated with 1,000 mg/kg clarithromycin. Red pulp atrophy was diagnosed in only one male mouse in the group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. For the female-A mice, however, the combination of 400 mg/kg AZT plus 500 mg/kg clarithromycin resulted in red pulp atrophy that was not found in the female-A group treated with 500 mg/kg clarithromycin alone, and the incidence and severity increased in the female-A group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. Lymphoid follicle atrophy occurred with a low incidence in male mice treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin and female-A groups treated with 200 or 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. Lymphoid follicle atrophy tended to occur in the same groups that had red pulp atrophy.

TABLE 6 Histopathological Alterations in the Spleen in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Hematopoietic Cell Proliferation^b^ | | Hemosiderin Pigmentation^b^ | | Lymphoid Follicle Depletion^b^ | | Red Pulp Atrophy^b^
| Males | Females-A | Males | Females-A | Males | Females-A | Males | Females-A
0 + 0 | 0/10 | 8/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20 | 0/10 | 0/20
0 + 250 | 1/10(2 0) | 13/20 (1 2) | 0/10 | 0/20 | 0/10 | 0/20 | 0/10 | 0/20
0 + 500 | 0/10 | 13/20 (1 1) | 0/10 | 0/20 | 0/10 | 0/20 | 0/10 | 0/20
0+1,000 | 4/10 (1 0) | 14/20 (1 1) | 0/10 | 0/20 | 0/10 | 2/20 (2 5) | 0/10 | 3/20 (2 0)
200+0 | 4/10 (1 0) | 14/20 (1 1) | 2/10 (1 0) | 8/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
200 + 250 | 5/10 (1 0) | 17/20 (1 1) | 3/10 (1 0) | 17/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
200 + 500 | 6/10 (1 5) | 19/20 (1 5) | 6/10 (1 0) | 19/20 (1 1) | 0/10 | 0/20 | 0/10 | 0/20
200+ 1,000 | 5/10 (1 2) | 17/20 (2 0) | 9/10 (1 8) | 19/20 (1 5) | 0/10 | 2/20 (2 0) | 0/10 | 4/20 (1 8)
400 + 0 | 9/10 (1 0) | 18/20 (1 3) | 4/10 (1 0) | 15/20 (1 0) | 0/10 | 0/20 | 0/10 | 0/20
400 + 250 | 4/10 (1 3) | 19/20 (1 5) | 7/10 (1 0) | 20/20 (1 8) | 0/10 | 0/20 | 0/10 | 0/20
400 + 500 | 4/10 (1 8) | 10/20 (1 1) | 8/10 (1 3) | 20/20 (2 2) | 0/10 | 0/20 | 0/10 | 10/20(1 2)
400 + 1,000 | 5/10 (1 6) | 5/20 (2 4) | 5/10 (1 4) | 19/20 (1 9) | 2/10 (2 0) | 1/20 (3 0) | 1/10 (4 0) | 15/20 (1 7)

a AZT + clarithromycin in mg/kg per day

b Number of animals with lesion/number of animals examined (mean seventy for mice with lesion, grade 1 =minimal, 2=mild, 3=moderate, 4=marked)

TABLE 7 Statistical Analysis of Mean Severity of Hematopoietic Cell Proliferation in the Spleen of Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females-A^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^d^ | Mean^e^ | S.E. | Ratio^d^
0 + 0 | 0 000 | 0 000 | NA | 0 333 | 0 167 | NA
0 + 250 | 0 200 | 0 200 | — | 0 750 | 0 143 | 225
0 + 500 | 0 000 | 0 000 | — | 0 700 | 0 128 | 210
0+1,000 | *0 400 | 0 163 | — | 0 800 | 0 138 | 240
| Trend^f^ | + (P=0 026) | | Trend^f^ | + (P=0 156)
| Test Used^g^ | Dunn | | Test Used^g^ | Dunn
200 + 0 | 0 400 | 0 163 | NA | 0 750 | 0 123 | NA
200 + 250 | 0 500 | 0 167 | 125 | 0 950 | 0 114 | 127
200 + 500 | 0 900 | 0 277 | 225 | **1 400 | 0 169 | 187
200 + 1,000 | 0 600 | 0 221 | 150 | »^**^1 700 | 0 231 | 227
| Trend^f^ | + (P=0 368) | | Trend^f^ | + (P<0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley
400 + 0 | 0 900 | 0 100 | NA | 1 200 | 0 138 | NA
400 + 250 | 0 500 | 0 224 | 56 | 1 450 | 0 170 | 121
400 + 500 | 0 700 | 0 300 | 78 | **0 550 | 0 135 | 46
400 + 1,000 | 0 800 | 0 291 | 89 | **0 600 | 0 245 | 50
| Trend^f^ | - (P=0 555) | | Trend^f^ | - (P<0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley

a Seventy grade presented as mean seventy (1=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S E)

b AZT + clarithromycin in mg/kg per day

c n=10

d (Dosed group mean/control group mean) x 100, NA = not applicable, — = ratio cannot be calculated

e n=20

f Direction and significance of trend (Jonckheere’s test)

g Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P<0 05)

** Significantly different from the control group (P<0 01)

TABLE 8 Statistical Analysis of Mean Severity of Hemosiderin Pigmentation in the Spleen of Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females-A^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^e^ | Mean^d^ | S.E. | Ratio^e^
0 + 0 | 0 000 | 0 000 | NA | 0 000 | 0 000 | NA
0 + 250 | 0 000 | 0 000 | — | 0 000 | 0 000 | —
0 + 500 | 0 000 | 0 000 | — | 0 000 | 0 000 | —
0 + 1,000 | 0 000 | 0 000 | — | 0 000 | 0 000 | —
| Trend^f^ | (P=l 000) | | Trend^f^ | (P=l 000)
| Test Used^g^ | Dunn | | Test Used^g^ | Dunn
200 + 0 | 0 200 | 0 133 | NA | 0 400 | 0 112 | NA
200 + 250 | 0 300 | 0 153 | 150 | **0 850 | 0 082 | 213
200 + 500 | 0 600 | 0 163 | 300 | **1 050 | 0 088 | 263
200 + 1,000 | **0 900 | 0 100 | 450 | **1 400 | 0 134 | 350
| Trend^f^ | + (P=0 001) | | Trend^f^ | + (P<0 001)
| Test Used^g^ | Shirley | | Test Used^g^ | Shirley
400 + 0 | 0 400 | 0 163 | NA | 0 750 | 0 099 | NA
400 + 250 | 0 700 | 0 153 | 175 | **1 750 | 0 123 | 233
400 + 500 | 1 000 | 0 211 | 250 | **2 200 | 0 092 | 293
400 + 1,000 | 0 700 | 0 260 | 175 | **1 850 | 0 131 | 247
| Trend^f^ | + (P=0 227) | | Trend^f^ | + (P<0 001)
| Test Used^g^ | Dunn | | Test Used^g^ | Shirley

a Seventy grade presented as mean seventy (l=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S E)

b AZT + clarithromycin in mg/kg per day

c n=10

d n=20

e (Dosed group mean/control group mean) × 100, NA = not applicable, — = ratio cannot be calculated

f Direction and significance of trend (Jonckheere’s test)

g Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P<0 05)

** Significantly different from the control group (P<0 01)

#### Thymus Lesions

Atrophy of the thymus (Table 9) occurred primarily in male and female-A mice treated with clarithromycin alone or in combination with AZT and was considered to be compound related. This alteration was also believed to be related to stress. Thymic atrophy was graded for severity based on the following criteria:

- Minimal severity - depletion of approximately 5% or less of cortical lymphocytes
- Mild severity - depletion of approximately 6% to 20% of cortical lymphocytes
- Moderate severity - depletion of approximately 21% to 50% of cortical lymphocytes.

For the male groups, the incidences of atrophy of the thymus (Table 9) were low and none of the severity grades (Table 10) were statistically significant (p<0.05). For the female-A group treated with 1,000 mg/kg clarithromycin, a significant (p<0.05) increase in severity occurred when compared to the untreated control group. Compared to the female-A group treated with 200 mg/kg AZT alone, a significant increase (p<0.01) in severity occurred in the group treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin. When compared to the group treated with 400 mg/kg AZT alone, significant dose-related increases (p<0.05 to P<0.01) in severity occurred in female-A groups treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin.

TABLE 9 Histopathological Alterations in the Thymus in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Atrophy^b^
Dose^a^ | Males | Females-A
0 + 0 | 0/10 | 0/20
0 + 250 | 0/10 | 1/20 (1 0)
0 + 500 | 0/10 | 0/20
0 + 1,000 | 1/10 (1 1) | 6/20 (1 7)
200 + 0 | 0/10 | 1/20 (1 0)
200 + 250 | 0/9 | 1/18 (1.0)
200 + 500 | 0/10 | 0/20
200 + 1,000 | 0/9 | 9/20 (1 6)
400 + 0 | 0/10 | 0/20
400 + 250 | 1/10 (1 0) | 4/20 (1 5)
400 + 500 | 3/10 (1 0) | 5/19 (2.2)
400 + 1,000 | 3/10 (2 3) | 11/18 (2 1)

a AZT + clarithromycin in mg/kg per day

b Number of animals with lesion/number of animals examined (mean seventy for mice with lesion, grade 1=minimal, 2=mild, 3=moderate, 4=marked)

TABLE 10 Statistical Analysis of Mean Severity of Thymic Atrophy in Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^b^ | Severity in Males^a^ | | | | Severity in Females-A^a^
Dose^b^ | n | Mean | S.E. | Ratio^c^ | n | Mean | S.E. | Ratio^c^
0 + 0 | 10 | 0 000 | 0 000 | NA | 20 | 0 000 | 0 000 | NA
0 + 250 | 10 | 0 000 | 0 000 | — | 20 | 0 050 | 0 050 | —
0 + 500 | 10 | 0 000 | 0000 | — | 20 | 0000 | 0000 | —
0+1,000 | 10 | 0 100 | 0 100 | — | 20 | *0 500 | 0 212 | —
| | Trend^d^ | + (P=0 180) | | | Trend^d^ | + (P=0 006)
| | Test Used^e^ | Dunn | | | Test Used^e^ | Shirley
200 + 0 | 10 | 0 000 | 0 000 | NA | 20 | 0 050 | 0 050 | NA
200 + 250 | 9 | 0 000 | 0 000 | — | 18 | 0 056 | 0 056 | 111
200 + 500 | 10 | 0 000 | 0 000 | — | 20 | 0 000 | 0 000 | 0
200+ 1,000 | 9 | 0 000 | 0 000 | — | 20 | **0 700 | 0 206 | 1,400
| | Trend^d^ | (P=l 000) | | | Trend^d^ | + (P=0 001)
| | Test Used^e^ | Dunn | | | Test Used^e^ | Shirley
400 + 0 | 10 | 0 000 | 0 000 | NA | 20 | 0 000 | 0 000 | NA
400 + 250 | 10 | 0 100 | 0 100 | — | 20 | *0 300 | 0 164 | —
400 + 500 | 10 | 0 300 | 0 153 | — | 19 | *0 579 | 0 257 | —
400+1,000 | 10 | 0 700 | 0 396 | — | 18 | **1 278 | 0 289 | —
| | Trend^d^ | + (P=0 031) | | | Trend^d^ | + (P<0 001)
| | Test Used^e^ | Dunn | | | Test Used^e^ | Shirley

a Seventy grade presented as mean seventy (l=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S E)

b AZT + clarithromyin mg/kg per day

c (Dosed group mean/control group mean) x 100, NA = not applicable, — = ratio cannot be calculated

d Direction and significance of trend (Jonckheere’s test)

e Multiple compansons test comparing dose group to control group

* Significantly different from the control group (P<0 05)

** Significantly different from the control group (P<0 01)

#### Bone Marrow Lesions

Depletion of the bone marrow (Table 11 and Plate 2) occurred primarily in male and female-A groups treated with combinations of AZT and clarithromycin. The bone marrow depletion occurred predominately in the erythrocytic series. Bone marrow depletion was graded for severity based upon the following criteria:

- Minimal severity - depletion of approximately 5% or less of cells of the erythrocytic series
- Mild severity - depletion of approximately 6% to 20% of cells of the erythrocytic series
- Moderate severity - depletion of approximately 21% to 50% of cells of the erythrocytic series
- Marked severity - depletion of greater than 50% of cells of the erythrocytic series.

Female-A mice treated for approximately 30 days appeared to be affected more severely than male mice, and the development of this lesion was believed to correspond with the increasing severity of anemia associated with the inability of the bone marrow to respond adequately. For the male mice treated for approximately 20 days, bone marrow depletion occurred only in groups treated with 200 or 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. One female-A mouse treated with 1,000 mg/kg clarithromycin alone developed bone marrow depletion. For the female-A groups treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin or 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the incidence and severity of bone marrow depletion, in general, increased as dosage levels increased.

TABLE 11 Histopathological Alterations in the Bone Marrow in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Cellular Depletion^b^
Dose^a^ | Males | Females-A
0 + 0 | 0/10 | 0/20
0 + 250 | 0/10 | 0/20
0 + 500 | 0/10 | 0/20
0+1,000 | 0/10 | 1/20 (2 0)
200 + 0 | 0/10 | 0/20
200 + 250 | 0/10 | 0/20
200 + 500 | 0/10 | 0/20
200+ 1,000 | 3/10 (10) | 6/20 (1 3)
400 + 0 | 0/10 | 0/20
400 + 250 | 0/10 | 7/20 (17)
400 + 500 | 0/10 | 18/20 (2 2)
400+ 1,000 | 4/10 (2 0) | 15/20 (2 9)

a AZT + clarithromycin in mg/kg per day

b Number of animals with lesion/number of animals examined (mean seventy for mice with lesion, grade l=minimal, 2=mild, 3=moderate, 4=marked)

#### Kidney Lesions

Nephropathy (Table 12) was diagnosed in male and female-A mice treated with clarithromycin alone. Nephropathy included a variety of changes that occurred predominantly in the renal tubules, including necrosis, regeneration, and cytoplasmic vacuolization of tubular epithelial cells in the cortex. The necrosis was evident from the outer medullary zone and corticomedullary junction to the periphery of the cortex. Necrosis was manifested by disruption of nuclear architecture accompanied by an eosinophilic granular material in the tubular lumens. Cytoplasmic vacuolization of tubular epithelial cells and regenerating basophilic epithelial cells were usually more obvious in the peripheral areas of the cortex. In severely affected kidneys, eosinophilic proteinaceous material and cellular debris were present in tubular lumens in the medulla. Criteria for the diagnosis of nephropathy were as follows:

- Minimal severity - approximately 10% or less of the renal cortex involved with the nephropathy
- Mild severity - approximately 11% to 25% of the renal cortex involved with the nephropathy
- Moderate severity - approximately 26 to 50% of the renal cortex involved with the nephropathy.

Nephropathy occurred in three male and seven female-A mice treated with 1,000 mg/kg clarithromycin alone (Table 12). Nephropathy was not diagnosed in male and female-A mice treated with AZT alone or with 250 or 500 mg/kg clarithromycin alone. Female-A mice appeared to be slightly more susceptible to the development of nephropathy than were male mice; however, the female-A mice were treated for approximately 30 days compared to approximately 20 days for the males. With combination therapy, the greatest incidence occurred in female-A mice treated with 1,000 mg/kg clarithromycin in combination with AZT. The nephropathy appears to be the result of treatment with clarithromycin as the incidence did not increase when combined with AZT.

TABLE 12 Histopathological Alterations in the Kidney in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Nephropathy^b^
Dose^a^ | Males | Females-A
0 + 0 | 0/10 | 0/20
0 + 250 | 0/10 | 0/20
0 + 500 | 0/10 | 0/20
0+ 1,000 | 3/10 (1 3) | 7/20 (1 7)
200 + 0 | 0/10 | 0/20
200 + 250 | 0/10 | 2/20 (1 0)
200+500 | 0/10 | 0/20
200 + 1,000 | 1/10 (10) | 5/20 (16)
400 + 0 | 0/10 | 0/20
400 + 250 | 0/10 | 0/20
400 + 500 | 1/10 (1 0) | 1/20 (3 0)
400 + 1,000 | 1/10 (2 0) | 5/20 (1 8)

a AZT + clarithromycin in mg/kg per day

b Number of animals with lesion/number of animals examined (mean seventy for mice with lesion, grade 1=minimal, 2=mild, 3=moderate, 4=marked)

#### Lymph Node Lesions

Minimal to moderate depletion of lymphocytes occurred in the mesenteric and mandibular lymph nodes of two female-A mice treated with 1,000 mg/kg clarithromycin alone. Minimal cellular depletion was manifested by a reduction of approximately 10% of the lymphocyte population, and moderate depletion consisted of a reduction of approximately 26% to 50% of the lymphocyte population. Cytoplasmic vacuolization of reticuloendothelial cells accompanied the lymphoid depletion. Both mice with depletion of lymphocytes in lymph nodes had concurrent thymic atrophy and cellular depletion of lymphoid follicles in the spleen. Cellular depletion in lymph nodes was not diagnosed in male mice treated with clarithromycin alone at any dose level, in any of the female-A groups treated with 250 or 500 mg/kg clarithromycin alone, or in male or female-A mice treated with combinations of 200 or 400 mg/kg AZT and 250,500, or 1,000 mg/kg clarithromycin.

#### Brain Lesions

A total of five mice had treatment-related lesions in the choroid plexus of the brain. Two female-A mice treated with 1,000 mg/kg clarithromycin alone, two female-A mice treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin, and one male mouse treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin had cytoplasmic vacuolization of cells of the choroid plexus. Severity grades ranged from minimal (involving up to approximately 25% of the cells of the plexus) to mild (involving approximately 25% to 50% of the cells of the plexus), and in general, cytoplasmic vacuolization in cells of the choroid plexus occurred concurrently in mice that had cytoplasmic vacuolization in other tissues having cells with phagocytic capability (e.g., liver, spleen, lymph nodes). Macrophages have been demonstrated in the choroid plexus of mice (Sturrock, 1983, 1988). Cytoplasmic vacuolization of cells in the choroid plexus was not diagnosed in any male or female-A mice treated with AZT alone at any dose level, any male or female-A mice treated with 250 or 500 mg/kg clarithromycin alone, or any male mice treated with 1,000 mg/kg clarithromycin alone. This likely reflected the shorter duration of treatment for the male groups (approximately 20 days) compared to the female-A groups (approximately 30 days).

#### Heart Lesions

Treatment-related lesions occurred in the heart of three mice (one female-A mouse treated with 1,000 mg/kg clarithromycin alone and one male and one female-A mouse treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin). The treatment-related heart lesions consisted of necrosis and hemorrhage of heart muscle, cytoplasmic vacuolization of valves, and degeneration of the atrium. The necrosis was manifested by disruption of the nuclear and cytoplasmic architecture accompanied by increased eosinophilia and a granular appearance. Vacuolization of the cytoplasm of cells in the heart valves resulted in a thickened to nodular appearance, and although the diagnosis of cytoplasmic vacuolization was documented in the valves, this cellular alteration was also present in cells of the endocardium and epicardium and around vessels extending into the heart muscle. Degeneration of the atrium was most obvious in the outer aspects of the wall of the atrium. The degenerative process consisted of cytoplasmic vacuolization of cells accompanied by edema and the deposition of granular eosinophilic material that may have been fibrin. The severity of the heart lesions ranged from minimal (involving up to approximetely 10% of the valves and the ventricular and atrial walls) to mild (involving approximetely 11% to 25% of the valves and the ventricular and atrial walls). Heart lesions did not occur in any of the male or female-A groups treated with AZT alone at any dose level, male or female-A groups treated with 250 or 500 mg/kg clarithromycin alone, or any of the lower dose combination groups.

#### Salivary Gland Lesions

Necrosis of the salivary gland occurred in two female-A mice treated with 1,000 mg/kg clarithromycin alone and in one male and one female-A mouse treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin. The salivary gland was present with many of the mandibular lymph nodes; however, not all salivary glands were evaluated. The severity ranged from minimal (pyknosis and karyorrhexis of up to approximately 10% of glandular epithelial nuclei) to mild (pyknosis and karyorrhexis of approximately 11% to 25% of glandular epithelial nuclei). Distortion of the normal glandular pattern accompanied the cellular necrosis.

#### Nontreatment-Related Lesions

Microscopic lesions not attributed to the administration of either compound were seen in male and female-A mice. These lesions occurred with no distinct pattern in a variety of different treatment groups. One of the most common lesions consisted of hypertrophy of bone. This lesion consisted of a combination of cartilaginous metaplasia, fibrosis, and/or necrosis that occurred locally on thoracic vertebrae or ribs near their junction with the vertebrae. The lesions were examined microscopically as a result of nodules or a deformity observed on the vertebrae or ribs at necropsy, and they were attributed to mechanical irritation caused by the gavage procedure. Other incidental lesions were focal necrosis and focal inflammation of the liver, inflammation or ulceration of the skin or subcutaneous tissue, inflammation of skeletal muscle, focal inflammation and hyperplasia of the lung or mediastinum, renal cyst, focal inflammation of the kidney, mineralization or inflammation of the heart, hyperplasia of the iliac lymph node, hemorrhage in the mesentery, inflammation of the salivary gland, and dilatation of the renal pelvis.

### Female-B Mice

Routine histopathological evaluations were not performed on female-B mice; however, gross lesions were processed and examined. Lesions in female-B mice believed to be related to treatment occurred only in the spleen and consisted of hematopoietic cell proliferation and hemosiderin pigmentation. For female-B groups treated with 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin and 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin, the respective incidences of hematopoietic cell proliferation of the spleen were one, one, one, and four. The degree of severity ranged from moderate to marked. Minimal hemosiderin pigmentation occurred in one, one, and three female-B mice treated, respectively, with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin and 400 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin. The lesions in the spleen were believed to correspond with the anemia that occurred in these groups.

## Sperm Function Evaluation

Administration of 200 or 400 mg/kg AZT and 250,500, or 1,000 mg/kg clarithromycin alone or in combination to male mice had no impact on male reproductive endpoints (Table D).

## Natural Delivery Data

Administration of 200 or 400 mg/kg AZT and 250,500, or 1,000 mg/kg clartihromycin alone or in combination to female-B mice had no effect (p<0.05) on the incidence of pregnancy (Table 13). Treatment with AZT alone or clarithromycin alone had no effect on the number of pregnant female-B mice that delivered litters. Combination therapy, however, had a distinct negative impact on the number of litters delivered. Slight declines in delivery rates occurred in female-B groups treated with 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin, and a distinct dose-related decline in delivery rates occurred in groups treated with 400 mg/kg AZT and clarithromycin. Respective delivery rates for female-B groups treated with 400 mg/kg AZT alone and in combination with 250, 500, or 1,000 mg/kg clarithromycin were 100%, 42.8% (p≤0.01), 26.7% (p≤0.01), and 0.0% (p≤0.01).

TABLE 13 Occurrence of Pregnancy in Female-B Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations^a^

Dose^b^ | No. Pregnant (%) | No. of Dams that Delivered (%)
0 + 0 | 15 (75 0) | 14 (93 3)
200 + 0 | 14 (70 0) | 14(100 0)
400 + 0 | 16 (80 0) | 16 (100 0)
0 + 250 | 15 (75 0) | 15 (100 0)
0 + 500 | 12 (60 0) | 11 (91 7)
0 + 1,000 | 14 (70 0) | 14 (100 0)
200 + 250 | 15 (75 0) | 15 (100 0)
200 + 500 | 14 (70 0) | 8 (57 1)^+^
200 + 1,000 | 11 (55 0) | 8 (72 7)
400 + 250 | 14 (70 0) | 6 (42 8)^**,▲▲^
400 + 500 | 15 (75 0) | 4 (26 7)^**,▲▲^
400 + 1,000 | 15 (75 0) | 0 (0 0)^**,▲▲^

a Number assigned to each group = 20

b AZT + clarithromycin in mg/kg per day

** Significantly different from the control group value (P≤0 01) by the Kruskal-Wallis test

+ Significantly different from the 200 + 0 group value (P≤0 05) by the Kruskal-Wallis test

▲▲ Significantly different from the 400 + 0 group value (P≤0 01) by the Kruskal-Wallis test

Combination therapy tended to increase the duration of gestation. The duration of gestation (Table 14) was increased in female-B groups treated with 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin, as well as the groups treated with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin. Respective mean durations of gestation for the above groups were 20.6 days, 20.8 days (p≤0.05), 21.0 days, and 20.5 days compared to 20.0 days for the controls. Administration of AZT or clarithromycin alone did not alter the duration of gestation.

For the dams treated with 400 mg/kg AZT alone, 18.8% had stillborn pups and 14.3% of dams treated with 1,000 mg/kg clarithromycin alone had stillborn pups (Table 14). For the female-B groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the percentages of dams with stillborn pups were, respectively, 13.3%, 25.0%, and 25.0%. There were no litters delivered in the group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin, and stillborn pups did not occur in groups treated with 250 or 500 mg/kg clarithromycin alone, 200 mg/kg AZT alone, or the groups treated with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin.

Although not statistically significant (p≤0.05), combination therapy caused declines in litter size (Table 14). For the groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, respective mean liveborn litter sizes were 10.5, 8.6, and 6.1 pups per litter. For the groups treated with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin, mean liveborn litter sizes were 5.2 and 6.8 pups per litter. There were no litters delivered in the group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin.

Prominent declines in viability indices (total number of pups surviving to postnatal day 4/total number of liveborn pups on day 0 postpartum x 100) occurred in female-B groups treated with the higher dose combinations (Table 14). In general, the mean number of surviving pups per litter on day 4 paralleled the treatment-related declines in the viability indices. The viability index in the group treated with 400 mg/kg AZT alone was slightly reduced (93.4%, P≤0.05). Further reductions occurred with combination therapy. For the group treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin, the viability index was 62.8% (p≤0.01). Respective indices for groups treated with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin were 33.3% (p≤0.01) and 81.5% (p≤0.01).

Administration of AZT alone or clarithromycin alone did not result in reduced pup weights. Pup weights per litter (Figure 11) were reduced for groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, with 400 mg/kg AZT alone, and with 400 mg/kg AZT plus 250 or 500 mg/kg clarithromycin.

TABLE 14 Summary of Significant Natural Delivery Litter Data for Female-B Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^a^ | Duration of Gestation (Days) | Dams with Stillborn Pups (%)^b^ | Dams with All Pups Dying on Days 0-4 (%)^b^ | Mean Liveborn Pups per Litter | Mean Surviving Pups per Litter Day 4 | Viability Index (%)^c^
0 + 0 | 20 0 | 0 (0 0) | 0 (0 0) | 12 0 | 11 8 | 98 2
200 + 0 | 20 2 | 0 (0 0) | 0 (0 0) | 11 1 | 11 1 | 99 4
400 + 0 | 20 1 | 3 (18 8) | 0 (0 0) | 12 2 | 11 4 | 93 4^*^
0 + 250 | 20 0 | 0 (0 0) | 0 (0 0) | 12 2 | 12 1 | 98 9
0 + 500 | 19 9 | 0 (0 0) | 0 (0 0) | 12 0 | 12 0 | 100 0
0 + 1,000 | 20 1 | 2 (14 3) | 0 (0 0)^d^ | 10 3 | 10 0 | 97 6
200 + 250 | 20 3 | 2 (13 3) | 0 (0 0)^d^ | 10 5 | 10 2 | 98 6
200 + 500 | 20 6 | 2 (25 0) | 0 (0 0)^d^ | 8 6 | 7 3 | 91 7+
200+ 1000 | 20 8^*^ | 2 (25 0) | 1 (12 5) | 6 1 | 3 8^**,++^ | 62 8^**,++^
400 + 250 | 21 0 | 0 (0 0) | 2 (33 3)^d^ | 5 2 | 1 0^**,▲▲^ | 33 3^**,▲▲^
400 + 500 | 20 5 | 0 (0 0) | 0 (0 0) | 6 8 | 5 5 | 81 5^**^
400 + 1,000^e^

a AZT + clarithromycin in mg/kg per day

b % of dams that delivered litters

c Number of live pups on day 4/number of liveborn pups on day 0 * 100

d Excludes values for litter found drowned

e No litters delivered

* Significantly different from control group (P≤0 05) by Cochran-Armitage and Fisher’s exact tests

** Significantly different from control group (P≤0 01) by Cochran-Armitage and Fisher’s exact tests

++ Significantly different from 200 + 0 group (P≤0 01) by Cochran-Armitage and Fisher’s exact tests

▲▲ Significantly different from 400 + 0 group (P≤0 01) by Cochran-Armitage and Fisher’s exact tests

FIGURE 11 Mean Body Weights per Litter of Female-B Pups in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

(LD=Lactation Day)

(LD=Lactation Day) *No litters were delivered)

## Caesarean Section Data

Slight declines in pregnancy rates (Table 15) occurred in female-A mice treated with 400 mg/kg AZT alone and 1,000 mg/kg clarithromycin alone. Compared to the control group, with a pregnancy rate of 100%, female-A groups treated with 200 or 400 mg/kg AZT had pregnancy rates of 80% and 75% (p≤0.05), respectively. For the groups treated with 250, 500, or 1,000 mg/kg clarithromycin, respective pregnancy rates were 95%,90%, and 70% (p≤0.05). Further declines in pregnancy rates occurred with combination therapy, and the declines appeared to parallel increasing doses of AZT and clarithromycin. For the groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, respective pregnancy rates were 95%,80%, and 45% (p≤0.01). For the groups treated with 400 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, respective pregnancy rates were 65% (p≤0.01), 20% (p≤0.01), and 10% (p≤0.01).

Litter size and the number of live fetuses per litter were altered by administration of AZT alone and clarithromycin alone (Table 16). Administration of AZT alone also caused a slight decline in litter size and the number of live fetuses per litter. Compared to the control group, which had 10.9 live fetuses per litter, groups treated with 200 or 400 mg/kg AZT had 8.2 and 4.3 (p≤0.01) live fetuses per litter, respectively. For groups treated with 250,500, or 1,000 mg/kg clarithromycin, there were 11.2, 10.9, and 9.8 live fetuses per litter. Combination therapy caused further declines in live litter size. For the groups treated with 200 mg/kg AZT plus 200, 500, or 1,000 mg/kg clarithromycin, there were 7.8,6.4 (p≤0.01), and 6.4 (p≤0.05) live fetuses per litter. For those treated with 400 mg/kg AZT plus 250, 500, or 1,000mg/kg clarithromycin, there were 2.3 (p≤0.01), 0.0 (p≤0.05), and 2.0 live fetuses per litter, respectively. Mortality in female-A dams did not influence the number of live fetuses per litter. Administration of AZT alone also increased the mean number of resorptions per litter (Table 16). The control group averaged 0.7 resorptions per litter, female-A mice treated with 200 or 400 mg/kg AZT had 3.6 (p≤0.01) and 5.1 (p≤0.01) resorptions per litter. Administration of 250, 500, or 1,000 mg/kg clarithromycin alone did not alter (p≤0.05) the mean number of resorptions per litter. Combination therapy increased the mean number of resorptions per litter. For the groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, the mean number of resorptions per litter were 4.0 (p≤0.01), 4.7 (p≤0.01), and 6.2 (p≤0.01), respectively. For those treated with 400 mg/kg AZT and the same dosages of clarithromycin, the respective mean number of resorptions were 8.2 (p≤0.01), 11.0 (p≤0.05), and 7.0 (p≤0.05) per litter.

TABLE 15 Occurrence of Pregnancy in Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^a^ | No. Assigned | No. Pregnant (%)
0 + 0 | 20 | 20(100 0)
200 + 0 | 20 | 16 (80 0)
400 + 0 | 20 | 15(75 0)^*^
0 + 250 | 20 | 19(95 0)
0 + 500 | 20 | 18(90 0)
0 + 1,000 | 20 | 14 (70 0)^*^
200 + 250 | 20 | 19(95 0)
200 + 500 | 20 | 16 (80 0)
200 + 1,000 | 20 | 9 (45 0)^**,+^
400 + 250 | 20 | 13(65 0)^**^
400 + 500 | 20 | 4 (20 0)^**,▲▲^
400 + 1,000 | 20 | 2 (10 0)^**,▲▲^

a AZT + clarithromycin in mg/kg per day

* Significantly different from control group (P≤0 05) by Cochran-Armitage and Fisher’s exact tests

** Significantly different from control group (P≤0 01) by Cochran-Armitage and Fisher’s exact tests

+ Significantly different from 200 + 0 group (P≤0 05) by Cochran-Armitage and Fisher’s exact tests

▲▲ Significantly different from 400 + 0 group (P≤0 01) by Cochran-Armitage and Fisher’s exact tests

TABLE 16 Summary of Significant Caesarean-Sectioning Litter Data for Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^a^ | Litter Size | Live Fetuses | | Dead Fetuses | | Resorptions
Dose^a^ | Mean ± SD | No. | Mean ± SD | No. | Mean ± SD | No. | Mean ± SD
0 + 0 | 10 9 ± 3 1 | 197 | 10 9 ± 3 1 | 0 | 0 0 ±0 0 | 13 | 0 7 ± 0 7
200 + 0 | 8 2 ± 3 0 | 131 | 8 2 ± 3 0 | 0 | 0 0 ± 0 0 | 58 | 3 6 ± 2 9^**^
400 + 0 | 4 3 ± 3 2^**^ | 64 | 4 3 ± 3 2^**^ | 0 | 0 0 ± 0 0 | 77 | 5 1 ± 3 4^**^
0 + 250 | 11 4± 1 9 | 180 | 11 2±2 1 | 3 | 0 2 ± 0 5 | 17 | 1 1 ± 1 3
0 + 500 | 11 0 ± 2 1 | 163 | 10 9± 2 1 | 2 | 0 1±0 4 | 16 | 1 1 ± 0 9
0+1,000 | 9 8 ± 4 4 | 117 | 9 8 ± 4 4 | 0 | 00±0 0 | 23 | 1 9±3 0
200 + 250 | 7 9 ± 5 1 | 141 | 7 8 ± 5 2 | 2 | 0 1 ±0 3 | 73 | 4 0± 3 4^**^
200 + 500 | 6 6± 3 4^**^ | 102 | 6 4 ± 3 4^**^ | 4 | 0 2 ± 0 4 | 75 | 4 7 ± 2 0^**^
200+ 1,000 | 6 8 ± 4 1^*^ | 58 | 6 4 ± 3 9^*^ | 3 | 0 3 ± 1 0 | 56 | 6 2 ± 2 9^**^
400 + 250 | 2 5 ±4 4^**^ | 30 | 2 3 ±4 3^**^ | 3 | 0 2 ± 0 4 | 107 | 8 2 ± 3 1^**^
400 + 500 | 0 0 ± 0 0^*^ | 0 | 0 0±0 0^*^ | 0 | 00±0 0 | 44 | 11 0 ± 3 8^*^
400+1,000 | 2 5 ± 3 5 | 4 | 2 0 ± 2 8 | 1 | 0 5 ± 0 7^*^ | 14 | 7 0 ± 1 4^*^

a AZT + clarithromycin in mg/kg per day

* Significantly different from control group (P≤ 0 05) by Cochran-Armitage and Fisher’s exact tests

** Significantly different from control group (P≤ 0 01) by Cochran-Armitage and Fisher’s exact tests

Fetal weights (Table 17) were reduced in all groups administered AZT either alone or in combination with clarithromycin. Although not statistically Significant (P≤ 0.05) when compared to the mean fetal weight in the control group (1.38 grams), groups treated with 200 or 400 mg/kg AZT had mean fetal weights of 1.24 and 1.17 grams, respectively. Significant (P≤ 0.05) declines in mean fetal weights did not occur in groups treated with clarithromycin alone. For the groups treated with 200 mg/kg AZT plus 250, 500, or 1,000 mg/kg clarithromycin, mean fetal weights were 1.04 grams (P≤0.05), 0.92 grams (P≤0.01), and 0.90 grams (P≤0.01), respectively. For the groups treated with 400 mg/kg AZT plus 250 or 1,000 mg/kg clarithromycin, respective mean fetal weights were 1.03 and 0.92 grams. There were no pups available for weighing in the group treated with 400 mg/kg AZT plus 500 mg/kg clarithromycin.

TABLE 17 Body Weights of Fetuses from Female-A Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Dose^a^ | Mean Fetal Weight (grams)
0 + 0 | 1 38
200 + 0 | 1 24
400 + 0 | 1 17
0 + 250 | 1 25
0 + 500 | 1 28
0 + 1,000 | 1 30
200 + 250 | 1 04^*^
200 + 500 | 0 92^**^
200+ 1,000 | 0 90^**^
400 + 250 | 1 03
400 + 500 | —
400 + 1,000 | 0 92

a AZT + clarithromycin in mg/kg per day

— No fetuses were present

* Significantly different from control group (P≤0 05) by Dunnett’s or Dunn’s test

** Significantly different from control group (P≤0 01) by Dunnett’s or Dunn’s test

## Gross External Alterations

A slight increase in the number of litters with fetuses with hydramnios occurred in the groups treated with 200 mg/kg AZT plus 500 or 1,000 mg/kg clarithromycin (Table 18). The fetal incidence was significant (p≤0.01) in the group treated with 200 mg/kg AZT plus 1,000 mg/kg clarithromycin. Similar increases probably did not occur in groups treated with 400 mg/kg AZT plus clarithromycin because of the reduced number of fetuses in these dose groups. There were no litters available for evaluation in the group treated with 400 mg/kg AZT plus 500 mg/kg clarithromycin and only one litter was available for evaluation in the group treated with 400 mg/kg AZT plus 1,000 mg/kg clarithromycin.

Other alterations included clubfoot of the hindlimbs, dark focus on the head, cranioschisis, hematoma on the head, pale body, dark focus on the body, spina bifida occulta, dark focus on the foot, dark eye, fetuses that were too small or fragile to sex or examine, and a nonspecified hematoma. These alterations were not believed to be related to treatment because the observation occurred in a control group litter, the observation may have been related to trauma, and/or the observation may reflect the mistiming of a single pregnancy.

TABLE 18 Summary of Fetal Gross External Alterations in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Observation | Dose^a^ | Litter Incidence^b^ | Fetal Incidence^c^
Hydramnios | 0 + 0 | 1 (5 6) | 13 (6 6)
Hydramnios | 200 + 0 | 2 (12 5) | 13 (9 9)
Hydramnios | 400 + 0 | 0 (0 0) | 0 (0 0)^*^
Hydramnios | 0 + 250 | 0 (0 0) | 0 (0 0)^**^
Hydramnios | 0 + 500 | 1 (6 7) | 13 (8 0)
Hydramnios | 0 + 1,000 | 0 (0 0) | 0 (0 0)^**^
Hydramnios | 200 + 250 | 0 (0 0) | 0 (0 0)^**,++^
Hydramnios | 200 + 500 | 4 (26 7) | 14 (14 0)
Hydramnios | 200 + 1,000 | 2 (25 0) | 16 (27 6)^**,++^
Hydramnios | 400 + 250 | 1 (14 3) | 2 (6 7)
Clubfoot hindlimbs | 0 + 0 | 6 (33 3) | 6 (3 0)
Clubfoot hindlimbs | 200 + 0 | 0 (0 0)^*^ | 0 (0 0)
Clubfoot hindlimbs | 400 + 0 | 1 (8 3) | 1 (16)
Clubfoot hindlimbs | 0 + 250 | 3 (18 8) | 3 (1 7)
Clubfoot hindlimbs | 0 + 500 | 1 (6 7) | 2 (12)
Clubfoot hindlimbs | 0 + 1,000 | 1 (9 1) | 1 (0 8)
Clubfoot hindlimbs | 200 + 250 | 0 (0 0)^*^ | 0 (0 0)
Clubfoot hindlimbs | 200 +500 | 0 (0 0)^*^ | 0 (0 0)
Head, dark focus | 400 + 1,000 | 1 (100 0)^d^ | 1 (25 0)
Head, cranioschisis | 200 + 500 | 1(6 7) | 1(1 0)
Head, hematoma | 200 + 0 | 1(6 2) | 1(0 8)
Body, pale | 200 + 500 | 1 (6 7) | 1 (1 0)
Body, pale | 400 + 1,000 | 1 (100 0)^d^ | 4 (100 0)
Body, dark focus | 200 + 500 | 1 (6 7) | 1 (1 0)
Body, spina bifida occulta | 200 + 500 | 1 (6 7) | 1 (1 0)
Too small and fragile to sex or examine | 0 + 0 | 1 (5 6) | 13 (6 6)
Too small and fragile to sex or examine | 200 + 0 | 1 (6 2) | 12 (9 2)
Too small and fragile to sex or examine | 400 + 0 | 0 (0 0) | 0 (0 0)^*^
Too small and fragile to sex or examine | 0 + 250 | 1 (6 2) | 13 (7 2)
Too small and fragile to sex or examine | 0 + 500 | 1 (6 7) | 13 (8 0)
Too small and fragile to sex or examine | 0 + 1,000 | 0 (0 0) | 0 (0 0)^**^
Too small and fragile to sex or examine | 200 + 250 | 1 (6 2) | 13 (9 2)
Too small and fragile to sex or examine | 200 + 500 | 0 (0 0) | 0 (0 0)^**,++^
Too small and fragile to sex or examine | 200 + 1,000 | 0 (0 0) | 0 (0 0)^+^
Right foot, dark focus | 0 + 1,000 | 1 (9 1) | 1 (0 8)
Right eye dark | 0 + 250 | 1 (6 2) | 1 (0 6)
Hematoma | 0 + 0 | 1 (5 6) | 2 (1 0)

a AZT + clarithromycin in mg/kg per day

b Data are presented as number of litters with the observation followed by percent (number of litters with the observation/number of litters evaluated)

c Data are presented as number of fetuses with the observation followed by percent (number of fetuses with the observation/number of fetuses evaluated, excludes dead fetuses)

d Excluded from statistical analyses as there was only one litter in the group

* Significantly different from control group (P≤0 05) by Dunnett’s or Dunn’s test

** Significantly different from control group (P≤0 01) by Dunnett’s or Dunn’s test

+ Significantly different from 200 + 0 group (P≤0 05) by Dunnett’s or Dunn’s test

++ Significantly different from 200 + 0 group (P≤0 01) by Dunnett’s or Dunn’s test

PLATE 1 Bone marrow from a control female-A mouse. (x400)

PLATE 2 Bone marrow from a female-A mouse treated with 400 mg/kg AZT + 500 mg/kg claritho showing cellular depletion. (x400)

PLATE 3 Choroid plexas in the brain of a control female-A mouse. (x400)

PLATE 4 Choroid plexus in the brain of a female-A mouse treated with 1,250 mg/kg clarithromycin showing cytoplasmic vacuoles in cells of the plexus. (x400)