# Materials and Methods

## Procurement and Characterization of Chemicals

3'-Azido-3'-deoxythymidine (AZT; Lots 7494-36-05 and 8404-120-03 RTI) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a powder. Clarithromycin was manufactured by Abbott Laboratories as tablets that included excipients. The tablets for the first study were crushed and sieved to a powder (Lots 8405-10-03 RTI and 8406-110-02 RTI). Clarithromycin for the second study was extracted from the tablets using acetone and was supplied as a powder (Lot 8408-54-01 RTI). Identification of both compounds was confirmed by nuclear magnetic resonance and infrared spectroscopy. The purity of both AZT and the extracted clarithromycin was determined by high-performance liquid chromatography to be greater than 99%. The concentration of clarithromycin in human-dosage tablets was determined by high-performance liquid chromatography to be 55.3%.

The control article was an aqueous solution containing 0.5% methylcellulose. The methylcellulose (Lot 876672) was procured from Fisher Scientific Co. (Pittsburgh, PA).

## Dose Formulations

Each test article was mixed singly with the control article or in combination with the control article. The dose formulations were then mixed until visually homogeneous. Stability studies indicated that AZT/clarithromycin formulations in 0.5% methylcellulose were stable for at least 28 days when stored at approximately 5° C protected from light. The dose formulations used in these studies were stored refrigerated in the dark and were used within 27 days of mixing.

Samples of dose formulations were analyzed for concentration. Animal-room samples from formulations remaining after dosing were also analyzed for concentration. Results showed AZT concentrations of 98.0% to 108% and clarithromycin concentrations of 92.0% to 108% of the theoretical concentrations with one exception; the clarithromycin concentration in the 400 + 250 mg/kg formulation was 77.6% of the theoretical concentration. Animal-room samples from the same dose formulations were 95.3% to 113% of the theoretical concentrations for AZT and 99.2% to 105% of the theoretical concentrations for clarithromycin at all dose concentrations.

## Study Design

Swiss (CD-1®) mice were obtained from Charles River Laboratories, Portage, MI (Area PO1), and were approximately 12 weeks old when placed on study. The mice were housed individually (males) or five per cage (females) during quarantine and were individually housed after randomization, except during cohabitation; they were housed in polycarbonate cages with solid bottoms and sides. All mice were uniquely identified by tail tattoo after randomization. The mice were housed in two rooms with equal numbers of each dose group and sex in each room. Average temperature in the animal rooms was 71.6° ± 1.40° F (SD) in Room 2 and 71.3° ± 1.29° F(SD) in Room 3; average relative humidity was 53.6% ± 3.37% (SD) in Room 2 and 51.2% ± 4.22% (SD) in Room 3.

Blood samples were collected from five sentinel animals per sex per room at terminal sacrifice as part of the animal disease screening program. Results indicated that all animals were free of viral antibodies.

AIDS patients are receiving combination therapy with clarithromycin and AZT. Controlled laboratory data are required to evaluate the potential toxicity of this combination therapy. At present, there are no adequate alternatives to whole animal models for this purpose. The Swiss mouse chosen for these studies is one of the mouse models routinely used for reproductive/developmental toxicity studies by the NIEHS.

The basic premise for dose selection is that the high-dose level should induce some measurable evidence of toxicity (e.g., anemia, weight loss, target organ toxicity). In a previous reproductive/developmental and toxicity study (NIEHS, 1999), AZT at the doses selected (200 and 400 mg/kg per day) caused resorptions and decreased litter sizes. Recent studies have also demonstrated dose-related decreases in hematologic parameters at these doses (NTP, 1999; NIEHS, 1999). The human therapeutic dose is 10 mg/kg per day (PDR, 1996). The selected doses were 20 and 40 times human doses, but on a body surface area basis, the doses were close to 2 and 4 times the therapeutic dose (Freireich, et al., 1966).

According to the information provided in the manufacturer’s insert (Abbott Laboratories package insert, 1998), the clinical dose of clarithromycin recommended for Mycobacterium avium complex (MAC) treatment in humans is 500 mg twice daily. Based on body surface area considerations, the dose levels of clarithromycin (250, 500, and 1,000 mg/kg per day) were approximately 1, 2, and 4 times the human therapeutic dose (Freireich, et al., 1966).

The design of this study is a modification of a design published by Harris et al. (1992). A brief summary is provided in Table 1. The oral route of administration was selected because it is the route used in humans. Combinations of AZT and clarithromycin were administered by gavage as a single formulation in an aqueous solution containing 0.5% methylcellulose. Concentrations of AZT in the formulations were 200 or 400 mg/kg body weight per day, and concentrations of clarithromycin were 250, 500, or 1,000 mg/kg day. Total daily doses of 20 mL/kg were divided into two equal doses of 10 mL/kg given approximately 6 hours apart. During the first study, due to the viscosity of the formulations, the concentrations were halved and the dose volume was increased to 40 mL/kg divided into two equal doses of 20 mL/kg given twice daily approximately 6 hours apart. Mice were divided into three groups as follows:

### Male Mice

Ten males were assigned to each dose group, each of which was divided into group 1 and group 2. Prior to dosing, male mice were cohabited with female-B mice on study days 0 through 4. Male mice were dosed beginning on study day 5 through the day prior to sacrifice (except for those designated for plasma concentration level determinations). Males were cohabited with female-A mice on study days 9 through 13 to identify any effects of treatment on mating behavior. On study day 25 or 26, all male mice were weighed, and blood samples were obtained from the retroorbital sinus for hematology and clinical chemistry evaluations. The males were then euthanatized with CO_2_, a gross necropsy was conducted, and the left testis and epididymis were collected and prepared for evaluation of sperm parameters as described in the Sperm Function Evaluation section. Eight additional male mice were assigned to selected dose groups to be used only for plasma AZT and clarithromycin concentration evaluations; these mice were treated on the same days as those assigned to the study, with the exception that they were dosed on the day of sacrifice. Body weight measurements for the extra males were used to calculate doses but were not reported.

### Female-A Mice

Twenty females were assigned to each dose group, each of which was divided into group 1 and group 2. Female-A mice were dosed beginning on study day 0 through the day prior to sacrifice (except for those designated for plasma concentration level determination). Male mice were cohabited with female-A mice on study days 9 through 13 to identify any effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. During cohabitation periods, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually and that day was designated as day 0 of gestation. At the end of the cohabitation period, all animals were housed individually. Prior to parturition on day 18 of presumed gestation (study days 28 to 32), all female-A mice were weighed, and blood samples were taken from the retroorbital sinus for hematology and clinical chemistry evaluations. Female-A mice were then euthanatized with CO_2_, and necropsy and caesarean section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative. The uterus of all sperm-negative females was examined for evidence of unsuccessful pregnancy, then press-plated between two heavy plates of glass to visualize implantation sites. Additional endpoints for all female-A mice included gravid uterine weight, number of implantation sites, resorptions, corpora lutea, and dead and live fetuses.

### Female-B Mice

Twenty females were assigned to each dose group, each of which was divided into group 1 and group 2. Prior to dosing, the group B females were cohabited with males on study days 0 through 4. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually and that day was designated as day 0 of gestation. At the end of the cohabitation period, sperm-negative female-B mice were euthanatized with CO_2_ and discarded without necropsy; all other animals were housed individually. Sperm-positive female-B mice were assigned as evenly as possible across dose groups prior to gestation day 6. Female-B mice were subsequently dosed during gestation days 6 through 15, during the fetal organogenesis period, to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. After gestation day 16, the bedding material and feeders were no longer changed. From gestation day 17 until the litters were delivered, female-B mice were observed twice daily for evidence of labor or delivery. The day delivery was completed was determined to the nearest day and was designated as postnatal day 0. On postnatal days 0 and 1, dam weights were recorded along with the number of live and dead pups, the number of male and female pups, gross malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, female-B mice, including any that did not deliver, were weighed and blood samples were taken for hematology determinations. After the mice were euthanatized with CO_2_, the uterus was removed and press-plated. All pups were weighed, given a thorough external examination for lesions or malformations, and the sex was recorded. The pups were then euthanatized with CO_2_ and saved in Bouin’s fixative.

### Clinical Pathology

Blood was drawn at terminal sacrifice from all mice (except males designated for plasma drug levels determinations) for hematology determinations and from male and female-A mice for clinical chemistry determinations. All blood samples were taken from the retroorbital sinus under CO_2_:O_2_ (70:30) anesthesia and were collected into tubes containing EDTA (hematology) or no anticoagulant (clinical chemistry). Animals were selected in random order for blood collection and samples were analyzed in the order collected. Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; leukocyte differentials; erythrocyte and platelet morphologies; and red cell distribution width were determined on whole blood using a Technicon H·1™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite™ flow cytometer. Blood smears were prepared to manually verify leukocyte differentials and morphologies if necessary, and platelet and erythrocyte morphological alterations were reported only in the raw data. Blood urea nitrogen, creatinine, alanine aminotransferase, total bile acids, alkaline phosphatase, and aspartate aminotransferase were determined based on sample availability using the Roche Cobas Fara™ automated analyzer.

### Plasma AZT and Clarithromycin Levels

Blood was collected by retroorbital puncture into heparinized tubes at 30, 60, 120, and 240 minutes following the last dose and was used for determination of AZT and clarithromycin levels in plasma. Two male and two female-A mice per selected dose group were bled at each time point when possible; selected groups were those receiving 400 mg/kg AZT alone, clarithromycin alone at all dose levels, and clarithromycin at all dose levels in combination with 400 mg AZT. Eight extra males were added to each of these dose groups to be used only for plasma drug level determinations. Pregnant female-A mice were used, when possible. These female-A mice were caesarean-sectioned and necropsied 1 day earlier than remaining female-A mice in anticipation of mortality following blood collection.

The plasma samples were analyzed for AZT and its metabolites, 3'-azido-3'-deoxythymidine β-D-glucuronide (GAZT), 3'-amino-3'-deoxythymidine (AMT), and 3'-amino-3'-deoxythymidine glucuronide (GAMT), and for clarithromycin by high performance liquid chromatography.

### Sperm Function Evaluation

The left testis from each male was removed at necropsy and weighed. The left epididymis was weighed, then the cauda epididymis was removed from the corpus. Sperm samples were collected from the cauda epididymis and mixed with modified Tyrode’s Solution on two prewarmed slides per animal. Slides were maintained at approximately 37° C and were viewed under a light microscope by two separate observers to assess sperm motility. The distal cauda of the epididymis was weighed then placed in a petri dish containing phosphate-buffered saline, and the tissue was teased to release the contents. The final caudal epididymal sperm suspension was incubated for at least 15 minutes. An aliquot was then further diluted with saline solution and placed in a bath of hot water for at least one minute to kill the sperm. Sperm density was determined using a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Necropsy and Histopathology

Necropsies were performed on all mice (except sperm-negative female-B mice) and histopathologic examiniations were conducted on the tissues listed in Table 1. All tissues were fixed in formalin, with the exception of the testis and epididymis, which were fixed in Bouin’s. The tissues were cut (5-Jμm sections) and representative sections were mounted on glass microscope slides and stained with hematoxylin and eosin (testis and epididymis stained with PAS). All tissues were examined microscopically by a veterinary pathologist and results were described using standard nomenclature.

TABLE 1 Experimental Design and Materials and Methods for the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

- Study Laboratory; Southern Research Institute, Birmingham, AL; - Strain and Species; Swiss (CD-1®) mice; - Animal Source; Charles River Laboratories, Portage, MI (Area P01); - Time Held Before Study; 15 days; - Average Age on Day 0 of Study; 86 days; - Date of Day 0; 5/30/97 for group 1 mice and 6/6/97 for group 2 mice; - Date of First Dose; Males day 5 (6/4/97 for group 1 and 6/11/97 for group 2 mice); Females-A day 0 (5/30/97 for group 1 and 6/6/97 for group 2 mice); Females-B gestation day 6 (6/6-10/97 for group 1 and 6/13-17/97 for group 2 mice); - Date of Last Dose; Males day prior to sacrifice (animals bled for plasma drug level determinations were dosed until the day of sacrifice); Females-A day prior to sacrifice (animals bled for plasma drug level determinations were dosed until the day of sacrifice); Females-B gestation day 15 (6/15-19/97 for group 1 and 6/22-26/97 for group 2 mice); - Days of Cohabitation; Males and Females-A days 9-13 (6/8-12/97 for group 1 and 6/15-19/97 for group 2); Males and Females-B days 0-4 (5/30-6/3/97 for group 1 and 6/6-10/97 for group 2); When possible, one male and two females within the same dosage group were housed together by consecutive animal number; - Necropsy Dates; Males days 25-26 (6/24-25/97 for group 1 and 7/1-2/97 for group 2); Females-A days 28-32 (gestation day 18, 6/27-7/1/97 for group 1 and 7/4-8/97 for group 2); Females-B postnatal day 4 (6/23-27/97 for group 1 and 6/30-7/4/97 for group 2), these dates were also days 24-28 of presumed gestation for sperm-positive mice that did not deliver Sperm-negative mice were euthanatized on day 5 (6/4/97 for group 1 and 6/11/97 for group 2) after cohabitation; - Average Age at Terminal Necropsy; Males 111-112 days; Females-A 114-118 days; Females-B 111-114 days; - Size of Study Groups; 10 or 18 males per dose group, 20 females-A per dose group, 20 females-B per dose group, each study group divided into group 1 and group 2; - Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups m random order; - Method of Animal Identification; Tail tattoo; - Diet; NIH-07 pelleted feed (Zeigler Bothers, Inc, Gardners, PA) available ad libitum, fresh feed provided weekly or as needed; - Water; Tap water (Birmingham municipal supply) via automatic watering system (Edstrom Industries, Inc, Waterford, WI) available ad libitum; - Cages; Polycarbonate cages with solid bottom and sides (Lab Products, Inc, Maywood, NJ), changed once weekly, except during delivery and lactation periods (gestation day 16 to teimmation) for female-B mice; - Bedding; Heat-treated hardwood bedding (P J Murphy Forest Products Corporation, Montville, NJ), changed once weekly, except during delivery and lactation periods (gestation day 16 to termination) for female-B mice; - Cage Filters; Reemay spun-bonded polyester (Dupont, Wilmington, DE), changed once every 2 weeks; - Racks; Stainless steel racks (Lab Products, Inc, Maywood, NJ), changed once every 2 weeks; - Animal Room Environment; Mean temperature 71 6° ± 1 40° F in Room 2 and 71 3° ± 1 29°F in Room 3, mean relative humidity 53 6% ± 3 37% m Room 2 and 51 2% ± 4 22% m Room 3 Minimum of 10 air exchanges per hour Fluorescent light 12 hours per day; - Doses; 0 mg AZT + 0 mg clarithromycin per kg body weight per day; 0 mg AZT + 250 mg clarithromycin per kg body weight per day; 0 mg AZT + 500 mg clarithromycin per kg body weight per day; 0 mg AZT + 1,000 mg clarithromycin per kg body weight per day; 200 mg AZT + 0 mg clarithromycin per kg body weight per day; 200 mg AZT + 250 mg clarithromycin per kg body weight per day; 200 mg AZT + 500 mg clarithromycin per kg body weight per day; 200 mg AZT + 1,000 mg clarithromycin per kg body weight per day; 400 mg AZT + 0 mg clarithromycin per kg body weight per day; 400 mg AZT + 250 mg clarithromycin per kg body weight per day; 400 mg AZT + 500 mg clarithromycin per kg body weight per day; 400 mg AZT + 1,000 mg clarithromycin per kg body weight per day; - Type and Frequency of Observations; Mortality/monbundity twice daily; Clinical signs once daily; Vaginal plugs days 10-14 for females-A, days 1-5 for females-B; Body weights days 3, 5, 9, 13, 17,21, 23, and sacrifice for males, days -1, 0,4,12, 16, 20,23,26, and sacrifice for females-A, gestation days 0, 8, 12, and 15 and postnatal days 0, 1, and 4 for females-B, postnatal days 0, 1, and 4 for F_1_, pups; - Clinical Pathology; Hematology and clinical chemistry evaluations were conducted on all males (except those designated for plasma AZT and clarithromycin level determinations) and females-A at terminal sacrifice, hematology evaluations were conducted on all females-B at terminal sacrifice; - Plasma AZT and Clarithromycin Levels; Selected males and females-A from selected dose groups were bled for plasma AZT, AZT metabolites, and clarithromycin determinations; - Sperm Function Evaluation; Conducted on all males at terminal sacrifice (except those designated for plasma AZT and clarithromycin level determinations); - Necropsy and Histopathologic Examinations; Complete necropsies were performed on all breeder animals except sperm-negative females-B The right epididymis of males, the gravid uterus of females-A, and the liver of males and females-A were weighed at necropsy The following were collected at necropsy, saved in formalin, and examined histopathologically Males and females-A - brain, bone marrow (femur), gross lesions, heart, kidneys, liver, lungs and bronchi, mandibular and mesenteric lymph nodes, spleen, and thymus, also right testis and epididymis of males Females-B - gross lesions Pups were examined externally only and saved

NOTE The study design shown above is specific for the second study With the exception of clarithromycin dose levels (500, 1,250, and 2,500 mg/kg per day), the design of the initial study (conducted 11/8/96 - 12/17/96) was essentially the same

## Statistical Methods

Paternal and maternal body weight evaluations were analyzed using Bartlett’s Test of Homogeneity of Variances (Sokal and Rohlf, 1969) and the Analysis of Variance (Snedecor and Cochran, 1967a), when appropriate. If Bartlett’s test was not significant (P>0.05) and the Analysis of Variance was significant (P≤0.05), then Scheffe’s test (1953) was used to identify the statistical significance of individual groups. If Bartlett’s test was significant (P≤0.05), then the Analysis of Variance was not appropriate and the Kruskal-Wallis test (Sokal and Rohlf, 1969) was used; in cases where the Kruskal-Wallis test was significant (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight (per litter), as well as all other evaluations involving continuous data. Observations for delivered and dead conceptuses of the female-A dams were excluded from fetal body weight summaries and statistical analyses.

Group means and standard deviations were calculated for hematology and clinical chemistry parameters and for terminal body and epididymis weights. Liver/body weight ratios were also calculated. Mean terminal body weights, mean liver weights, and liver/body weight ratios for each treated group were compared to those of the control group by a two-tailed Student’s t-test for each sex. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and treated groups. Hematology and clinical chemistry data were evaluated using Dunnett’s (1955) test.

Sperm end points (i.e., terminal body, epididymis, cauda epididymis, and testis weights, sperm motility, and sperm concentration) were analyzed using a two-way analysis of variance. Statistical significance in the absence of significant interaction between AZT and clarithromycin was indicative of a treatment-related effect. If the interaction was not statistically significant, control and treated group means were compared using a multiple comparison procedure; Williams’ test (1971, 1972) was applied if there was an indication of trend (p<0.01), and Dunnett’s test (1955) was used in the absence of a trend, as assessed by Jonckheere’s test (1954).

Proportion data (e.g., clinical observation data and the incidences of pregnancy, resorption, death, and total resorption) for presumed pregnant mice were analyzed using the Cochran-Armitage test for a linear trend in proportions (Snedecor and Cochran, 1967b) and Fisher’s exact test (Siegel, 1956).