# Introduction

Acquired immunodeficiency syndrome (AIDS) is a lethal multisystem disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegle et al., 1981). The etiological agent of AIDS is a retrovirus that is now referred to as the human immunodeficiency virus (HIV) (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3'-azido-3'-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in lifespan (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss CD-1® mice were administered 100, 250, 500, or 1,000 mg AZT/kg body weight by gavage for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematological results and included lymphoid depletion, reticuloendothelial hyperplasia in the spleen and thymus, and bone marrow hypocellularity.

In a 14-weekstudy (NTP, 1999), B6C3F_1_ mice were treated with 0, 25,50,100,400, or 1,000 mg of AZT/kg body weight administered by gavage twice daily with one half the total dose in 0.5% methylcellulose. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups were administered 0,50,400, or 1,000 mg/kg AZT twice daily for 14 weeks and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical finding in AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle (Rao et al., 1998).

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose-proportional over the oral dose concentration range administered.

Standard teratology studies of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes postdosing were 61 μg/g or 76 times the antiviral ID_50_. Rabbits were dosed orally at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes postdosing were 40.2 μg/g, or 50 times the antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal body weight gain, feed consumption, hematological parameters, or growth and survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in C3H/He mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female mice were exposed to 0, 0.25, 0.5, or 2.5 mg AZT/mL drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Because AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992). As a result, the treatment of AIDS is increasingly one of combination therapy of anti-HIV drugs and anti-infective drugs (Goldschmidt and Dong, 1992). Disseminated infection with the Mycobacterium avium complex (MAC) is the most common cause of bacteremia in AIDS patients, occurring in as many as 50% of these patients (Masur, 1993; Ong, 1999). MAC disease encompasses infections due to the bacterial organisms M. avium and M. intracellulare and to some strains of mycobacteria not yet identified (Faris et al., 1998). These organisms are atypical acid-fast bacilli and are usually not pathogenic to the healthy host.

MAC mycobacteria are ubiquitous organisms that can be isolated from water, soil, and a variety of animals, including dogs, cats, chickens, pigs, and insects (Masur, 1993). MAC infection was historically associated with chronic lung disease and received little attention. Infection occurs via respiratory or gastrointestinal routes, and the gastrointestinal tract is thought to be the most common site of colonization and dissemination. Survival of AIDS patients with MAC infection is half that of non-MAC-infected patients.

Disseminated MAC is rarely the initial AIDS-defining illness, because it occurs later in the course of the disease (Faris et al., 1998), and the incidence of MAC infection increases as average survival time increases due to better antiretroviral therapy. The signs and symptoms of MAC infection are nonspecific and include fever, night sweats, diarrhea, abdominal pain, weight loss, anorexia, nausea, vomiting, anemia, and elevated serum alkaline phosphatase. The effect of untreated disseminated disease in AIDS patients is unknown, although several studies have suggested that it is associated with decreased survival (Chaisson et al., 1992).

Current therapeutic recommendations for MAC are that all HIV-infected adults and adolescents with a CD4 lymphocyte count below 50 cells/mm^3^ receive clarithromycin at 500 mg twice a day or azithromycin at 1,200 mg once a week (CDC, 1997; Abbott Laboratories, 1998; Wright et al., 1998). Although azithromycin and clarithromycin appear to be similar in efficacy with regard to preventing disseminated MAC, clarithromycin is the only agent currently associated with a survival benefit in a well-controlled trial (Wright et al., 1998). The efficacy of clarithromycin in treatment of disseminated MAC in AIDS patients has been assessed in several clinical trials. Clarithromycin showed significant activity against MAC, and was well tolerated (Dautzenberg et al., 1991a,b, 1992, 1993; Saint-Marc and Touraine, 1991; Gupta et al., 1992). In one early clinical trial, AIDS patients with disseminated MAC receiving twice daily doses of 1,000 mg clarithromycin showed significant decreases in colony-forming units of M. avium in blood (Dautzenberg et al., 1991a), and in a second, multicenter trial with 77 AIDS patients, clarithromycin was effective in eradicating the organism from the blood in 63% of patients receiving doses of 500 to 1,000 mg/day and in 98% of patients receiving doses of 1,500 to 2,000 mg/day (Dautzenberg et al., 1993). Patients reported a significant improvement in the quality of life. However, there was a tendency toward relapse after discontinuation of the drug and toward development of resistance by the bacteria after prolonged monotherapy. In a recent risk-benefit assessment of therapies for MAC, Griffith (1999) concluded that monotherapy with clarithromycin at any of the dosages tested was frequently followed by a clarithromycin-resistant isolate. Therefore, as in the standard treatment of infections with Mycobacterium tuberculosis, it appears that monotherapy with clarithromycin for M. avium is not adequate due to the development of resistance and that cotreatment with other antibacterial drugs is necessary. One clinical trial of clarithromycin, ciprofloxacin, and amikacin in AIDS patients showed this combination to be effective against MAC infections in patients with bacteremia (Goldman and Longworth, 1993).

The in vitro activity of clarithromycin against various strains of mycobacteria has been assessed by numerous investigators (Brown et al., 1992; Heifets et al., 1992; Barradell et al., 1993; Alvarez-Elcoro and Enzler, 1999). Data have consistently shown that clarithromycin is effective at inhibiting the growth of these organisms and that the drug has greater in vitro activity against mycobacteria than other similar macrolide antibiotics. Evidence from in vitro studies and studies in the beige mouse suggest that clarithromycin may be synergistic with ethambutol and rifampin and additive with clofazimine (Sturgill and Rapp, 1992).

Clarithromycin may also be beneficial in the treatment of encephalitis caused by Toxoplasma gondii in AIDS patients (Fernandez-Martin et al., 1991). Infection with the intracellular coccidian protozoan T. gondii is a fairly common occurrence in birds and mammals, including humans. Such infections are typically benign and self-limiting in patients with healthy immune systems. However, toxoplasmosis can present a significant hazard to immunocompromised hosts (such as AIDS patients) or when the infection is contracted in utero (Saint Georgiev, 1994). More than 3,000 congenital pediatric cases of toxoplasmosis are reported annually. In its most common form in immunodeficient hosts, the disease manifests as toxoplasmic encephalitis, which is fatal if not treated. Toxoplasmic encephalitis is the major cause of focal intracerebral lesions in AIDS patients and results in significant morbidity and mortality in this population. Less commonly, toxoplasmosis can manifest as either a severe interstitial pneumonitis or myocarditis.

Clarithromycin and other macrolides (e.g., spiramycin, roxithromycin) have been shown to be effective against T. gondii both in vitro and in murine models. In an in vitro study using murine macrophages, clarithromycin effectively inhibited the growth of extracellular parasites; however, it was effective against intracellular parasites only at concentrations that were toxic to the host macrophages (Chang and Pechère, 1988). In vivo, various investigators have tested the efficacy of clarithromycin alone and in combination with pyrimethamine, minocycline, or sulfadiazine in mice experimentally infected with T. gondii (Araujo et al., 1992; Alder et al., 1994). Araujo et al. (1992) found that clarithromycin was protective against acute infections with several strains of T. gondii, including some isolated from AIDS patients, although the degree of protection varied with different strains of the parasite. Survival was enhanced by cotreatment with clarithromycin and either pyrimethamine or sulfadiazine. In chronically infected mice, cotreatment with clarithromycin and minocycline resulted in greater activity than either drug alone. In a similar series of experiments, Alder et al. (1994) tested the activity of clarithromycin, both alone and in combination with pyrimethamine or minocycline, against T. gondii in two strains of mice. Clarithromycin in combination with either pyrimethamine or minocycline was significantly more effective at increasing survival of experimentally infected mice than was any of the three drugs alone. The efficacy of the drug combinations was comparable to the standard pyrimethamine-sulfonamide or pyrimethamine-nonsulfonamide therapy. These authors concluded that measures of the in vitro efficacy of clarithromycin were not predictive of in vivo efficacy.

Fernandez-Martin et al. (1991) tested the efficacy of a clarithromycin-pyrimethamine combination against T. gondii in AIDS patients with primary toxoplasmic encephalitis. Patients received 2 g clarithromycin/day and 75 mg pyrimethamine/day for 6 weeks. Complete clinical remission was seen in six of the eight patients that completed the trial. The most common adverse effects were nausea (38%), skin rash (38%), elevated liver enzymes (24%), hearing loss (15%), and hematologic abnormalities, including anemia and thrombocytopenia (31 %). In terms of both efficacy and the incidence of adverse effects, the authors considered the clarithromycin-pyrimethamine combination to be comparable to standard therapies. Prophylactic monotherapy with clarithromycin is not currently recommended for toxoplasmic encephalitis (CDC, 1997).

Clarithromycin is a semisynthetic compound that belongs to the class of antibiotics known as macrolides, which are so called because they contain a macrocyclic lactone ring (Barradell et al., 1993). It occurs as a white to off-white crystalline powder and is soluble in acetone, slightly soluble in alcohol, and virtually insoluble in water. Clarithromycin is also known by a variety of other names, including TE-031 and A-56268 (Bahal and Nahata, 1992).

Clarithromycin, like erythromycin and many other macrolides, contains a 14-membered lactone ring. Structurally, it differs from erythromycin in that it contains a methoxy group, instead of a hydroxyl group, at position 6 of the lactone ring. Because of this modification, clarithromycin exhibits significantly improved pharmacokinetic properties and generally lower toxicity than erythromycin and some of the other macrolides. One persistent problem with erythromycin has been its instability under the acidic conditions of the stomach. At acid pH, erythromycin degrades to form first an 8,9-anhydro-6,9-hemiketal, which is then further degraded to erythromycin-6,9; 9, 12-spiroketal. Although neither of these degradation products exhibits significant antibacterial activity, the hemiketal is thought to be at least partially responsible for the gastrointestinal irritation that is common in patients taking erythromycin (Kirst and Sides, 1989; Bahal and Nahata, 1992). However, by blocking both hemiketal and spiroketal formation, the 6-methoxy group of clarithromycin confers on this drug a much improved acid stability. The 6-methoxy substitution has at least two other positive effects in that, besides providing for increased intragastric and intracellular stability of the drug, it also results in a lower incidence of adverse gastrointestinal effects than erythromycin by decreasing the ability of the drug and its metabolites to stimulate gastric motility, and it allows increased oral bioavailability of the drug (Sturgill and Rapp, 1992; Pallasch, 1993).

Clarithromycin is rapidly absorbed following oral administration, with a time-to-maximum-concentration of 1 to 2 hours after a 250 mg dose. Total bioavailability of the drug at this dose is approximately 55% (Goldman and Longworth, 1993). The presence of food in the stomach has been reported to slightly delay absorption (Sturgill and Rapp, 1992), to have no effect on absorption (Pallasch, 1993), or to slightly increase the rate of absorption of the drug (Bahal and Nahata, 1992). In any case, food does not affect total bioavailability of the drug or its metabolites (Abbott Laboratories, 1998).

After absorption, clarithromycin is well distributed in tissues, especially the lung. In mice, studies with radiolabeled clarithromycin showed that it is concentrated in almost all tissues and organs at higher concentrations than in blood and that it is especially prone to accumulate in the lungs, gastrointestinal tract, liver, kidney, and spleen (Kohno et al., 1990a). Uptake into lung cells is believed to be an energy-dependent active transport process (Kohno et al., 1990b). Clarithromycin is primarily metabolized in the liver by the cytochrome P-450 system. The major metabolite is 14-OH-clarithromycin, which has antibacterial activity comparable to the parent compound (Stein and Havlichek, 1992). Minor metabolic pathways, which produce metabolites with little or no biological activity, include N-demethylation and cleavage of the cladinose sugar.

After oral dosing in healthy humans (250 mg twice daily), clarithromycin and its 14-OH metabolite reach peak serum concentrations of 0.8 μg/mL and 0.6 μg/mL, respectively. These serum levels are attained in approximately 1 to 2 hours, and steady state concentrations of both the parent drug and the 14-OH metabolite are reached in 2 to 3 days (Goldman and Longworth, 1993). After a dose of 250 mg every 12 hours, the half-life of elimination is 3 to 4 hours for clarithromycin and 5 to 6 hours for the 14-OH metabolite. This, along with the low gastrointestinal toxicity of the drug, allows for twice daily dosing with clarithromycin, compared to four daily doses that are often required for erythromycin. However, formation of 14-0H-clarithromycin and elimination of clarithromycin and its metabolite exhibit a significant dose-related nonlinearity. Following a 1,200 mg dose of ^14^C-clarithromycin, total recovery of the 14-OH metabolite was reduced by 40%, and recovery of the parent drug was increased by 75%, compared to a single 250 mg dose (Ferrero et al., 1990). After twice daily dosing at 500 mg/dose, the elimination half-life for the parent drug increased to 5 to 7 hours. This nonlinearity in metabolism and elimination is thought to be due to saturation of the cytochrome P-450 and secondary metabolic pathways (Sturgill and Rapp, 1992).

Unlike some other macrolides (e.g., azithromycin) that undergo significant concentration in the tissues at the expense of serum levels, clarithromycin maintains relatively high serum concentrations (Stein and Havlichek, 1992). However, although the drug concentrates in tissues, significant accumulation does not occur. In one study, 4 hours after an oral dose of 500 mg in humans, clarithromycin concentrations in the lung were 17.5 mg/kg, compared to 2.5 mg/L in serum. After an additional 8 hours, concentrations had declined to 3.8 mg/kg and 0.4 mg/L for lung tissue and serum, respectively (Franschini et al., 1991a). Similar results have been described for both the parent drug and the 14-OH metabolite using different doses and dosing regimens (Franschini et al., 1991b).

Although both clarithromycin and its 14-OH metabolite are excreted primarily by the kidney, some biliary excretion does occur. After a 250 mg oral dose in adults humans, approximately 20% to 30% is excreted unchanged in the urine. Renal clearance is relatively unaffected by dose and approximates the glomerular filtration rate. However, damage to the kidney can have a profound effect on urinary excretion. Although the half-lives for urinary clearance for the parent and the 14-OH metabolite are 5.8 and 7.2 hours, respectively, when kidneys are functioning normally (creatinine clearance [CL_cr_] greater than 80 mL/min), these half-lives increase dramatically (9.6 and 16.9 hours at CL_cr_ =30 to 80 mL/min; and 19.8 and 28.9 hours at CL_cr_ less than 30 mL/min) when kidney function is compromised (Chu et al., 1991).

Several authors have reported on the interactions of clarithromycin with other drugs used in the treatment of AIDS patients (Richens et al., 1990; Albani et al., 1993; Gustavson et al., 1993; Honig et al., 1993; Piscitelli et al., 1996; McConnell and Amsden, 1999; Malaty and Kuper, 1999). Clarithromycin may increase the rate of AZT absorption in AIDS patients, but this does not appear to have a significant impact on the overall bioavailability of AZT (Vance et al., 1995). Another study (Polis et al., 1997) demonstrated that simultaneous administration of AZT and clarithromycin appears to decrease the level of AZT in serum.

Overall, clarithromycin, like most of the macrolide antibiotics, exhibits fairly low acute toxicity. The acute oral LD_50_ is greater than 5 g/kg in ICR mice and CD rats and greater than 3 g/kg in Wistar rats. There was no difference in toxicity between juvenile and adult rats, although the LD_50_ values for weanling rats were considerably lower than for the older rats (1.2-1.3 g/kg). Treated weanlings showed reductions in suckling behavior and spontaneous movement. No clarithromycin-related pathological lesions were seen. There was no apparent sex difference in sensitivity to clarithromycin at any age tested in acute studies (Craft and Siepman, 1993).

In several longer-term studies, the subchronic toxicity of clarithromycin was assessed in weanling and juvenile rats given daily oral doses for 2 to 6 weeks, with and without recovery periods. The dose in Wistar rats in a subchronic study at which no adverse effects occurred ranged from greater than 12.5 mg/kg per day to 55 mg/kg per day for juveniles and 8 to 50 mg/kg per day for adults. In the juvenile rats, most toxicity occurred at doses of 150 to 200 mg/kg per day, which is approximately 10 to 13 times the anticipated human dose (15 mg/kg per day). Toxic effects included dose-related decreases in feed consumption and body weight gain; erythema; salivation; alterations in a variety of hematologic and clinical chemistry parameters, including elevations in serum glucose and urine pH levels; and increases in liver and kidney weights. Mild vacuolar degeneration of the bile duct epithelium was apparent at doses of 150 to 800 mg/kg per day. The depressions in feed consumption and body weight gain normalized over the course of the studies, and most of the other adverse effects were reversible during recovery phases (Craft and Siepman, 1993; Guay et al., 1993).

In beagles treated daily for up to 6 weeks with clarithromycin, the highest dose with no toxic effect was 100 mg/kg per day in juveniles and 4 to 100 mg/kg per day in adults (Craft and Siepman, 1993; Guay et al., 1993). Vomiting occurred at doses higher than 30 mg/kg per day. At doses higher than 100 mg/kg per day, toxic effects included fatty deposition in both the liver and the kidney, cellular infiltration in the hepatic portal area, gastric glandular and thymic atrophy, cholecystitis, splenic lymphoid hyperplasia, anemia, ocular opacity, and increased liver, kidney, spleen, adrenal gland, and lung weights. Mortality was seen at doses of 100 to 400 mg/kg per day, and deaths at the higher doses were attributed to generalized organ degeneration. The authors reported no effect on cartilaginous growth plates in the younger animals.

In seven longer-term (unspecified duration) toxicity studies in monkeys (Guay et al., 1993), the doses at which there were no toxic effects ranged from 25 to 100 mg/kg per day. Toxic effects observed in one or more studies at doses of 75 to 150 mg/kg per day usually normalized during the recovery period. When given orally, 150 mg/kg per day in monkeys is equivalent to approximately 2.4 times the recommended maximum human dose on a mg/m^2^ basis (Abbott Laboratories, 1998). Toxic effects in monkeys consisted of reductions in feed consumption and body weight gain due to drug-induced vomiting, hypertransaminasemia, fatty changes in the liver, and increased liver, adrenal gland, and kidney weights. At higher doses (200 to 400 mg/kg per day), there were also lymphoid depletion, corneal opacity, fatty changes in renal cortical tubules, and histopathological changes in liver, thymus, stomach, and testes. At 100 mg/kg per day, death resulted from aspiration pneumonitis secondary to drug-induced vomiting. Hepatic and renal damage occurred at 150 mg/kg per day and widespread parenchymal damage occurred in 90% of animals receiving 400 mg/kg per day.

Because of the renal toxicity seen in experimental animals at doses tenfold higher than the expected human dose of clarithromycin, tests were conducted in healthy human male volunteers to determine the renal toxicity. These volunteers received 500 mg clarithromycin every 12 hours for 13 doses, and their urinary levels of alanine aminopeptidase and N-acetyl-glucosaminidase were measured. Clarithromycin failed to produce an increase in either urinary enzyme, and the authors concluded that the drug is unlikely to produce significant nephrotoxicity at normal human doses (Chapelsky et al., 1992).

The reproductive and developmental toxicity of clarithromycin has been evaluated in rats, mice, rabbits, and monkeys (Abbott Laboratories, 1998). Rats receiving daily doses of 150 to 160 mg/kg per day experienced no adverse effects on estrous cyclicity, fertility, parturition, or number or viability of pups, although the drug reached plasma levels twice those found in humans at the normal therapeutic dose. In primates given 150 mg/kg per day, plasma drug levels reached three times the human level and caused embryonic loss, although the fetotoxic effects of the drug were attributed to maternal toxicity accompanying the high dose rather than to direct fetotoxicity. Rabbits appear to be more sensitive to the reproductive toxicity of clarithromycin than other species tested. Pregnant rabbits receiving intravenous doses of 33 mg/m^2^ (17 times lower than the maximum proposed human dose) suffered in utero fetal loss.

At least four teratogenicity studies of clarithromycin have been conducted in Wistar rats, three by the oral route and one by the intravenous route. The drug was administered during the period of major organogenesis at 160 mg/kg per day, and no teratogenic effects were observed. However, in other studies where Sprague-Dawley rats were given 150 mg/kg per day during gestational days 6 to 15,2% to 6% of pups had cardiovascular or organ positional abnormalities (Guay et al., 1993). Plasma drug levels in these rats reached twice human levels. In four studies conducted in mice, 500 to 1,000 mg/kg per day given during gestational days 6 to 15 produced a 3% to 30% incidence of cleft palates. Plasma drug levels in these mice were approximately 17 times those seen in humans after a normal therapeutic dose.

Two studies of the developmental toxicity of clarithromycin have been conducted in rabbits (at daily oral doses of up to 125 mg/kg and intravenous doses of 30 mg/kg administered during gestation days 6 to 18). As in the rats, no teratogenic effects were observed.

The reproductive and developmental toxicity of clarithromycin was tested in macaques given daily oral doses of 35 or 70 mg/kg. These doses produced no drug-related embryolethal, fetotoxic, or teratogenic effects, although 70 mg/kg did result in fetal growth retardation. However, there was significant maternal toxicity at 70 mg/kg, manifested mostly by vomiting, diarrhea, and decreased feed consumption and weight gain, and there was some question whether the observed growth retardation in the offspring was secondary to maternal toxicity. Plasma drug levels were twice human levels. No adequate and well-controlled reproductive toxicity studies have been conducted in pregnant women.

## Study Rationale

Disseminated infection with MAC is one of the most common opportunistic infections in AIDS patients (Masur, 1993; Ong, 1999). AIDS patients with MAC receive combination therapy with an antiretroviral drug such as AZT and an antibiotic such as clarithromycin (CDC, 1997; Abbott Laboratories, 1998; Wright et al., 1998), which is highly useful in treatment of disseminated MAC. Information on toxicity of AZT alone and clarithromycin alone is available. However, reproductive, developmental, and general toxic effects of AZT and clarithromycin combinations in animal models are not available. These reproductive, developmental, and general toxicity studies of the combination of AZT and clarithromycin in an animal model was conducted by the NIEHS as a part of the program to evaluate the toxicity of drugs, especially combination therapies used in the treatment of AIDS patients with opportunistic infections.