# APPENDIX D Male Reproductive Tissue Evaluations

TABLE D1 Summary of Male Reproductive Tissue Evaluations in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations in Swiss (CD-1®) Mice

Dose^a^ | Left Caudal Weight (g) | Left Epididymal Weight (g) | Left Testicular Weight (g) | Epididymal Sperm Motility (%)
0 + 0 | 0 0195 ± 0 0012 (10)^b^ | 0 0476 ± 0 0026 (10) | 0 1256 ± 0 0042 (9) | 73 56 ± 178 (8)
0 + 250 | 0 0200 ± 0 0009 (10) | 0 0498 ± 0 0015 (10) | 0 1270 ± 0 0037 (10) | 74 50 ± 1 23 (9)
0 + 500 | 0 0198 ± 0 0009 (10) | 0 0490 ± 0 0013 (10) | 0 1173 ± 0 0040 (10) | 68 48 ± 3 24 (10)
0 + 1,000 | 0 0195 ± 0 0008 (10) | 0 0500 ± 0 0012 (10) | 0 1227 ± 0 0060 (10) | 68 33 ± 3 02 (10)
200 + 0 | 0 0209 ± 0 0008 (10) | 0 0512 ± 0 0013 (10) | 0 1272 ± 0 0062 (10) | 65 36 ± 3 40 (8)
200 + 250 | 0 0208 ± 0 0013 (10) | 0 0491 ± 0 0023 (10) | 0 1181 ± 0 0071 (10) | 60 42 ± 5 92 (9)
200 + 500 | 0 0196 ± 0 0011 (10) | 0 0499 ± 0 0024 (10) | 0 1266 ± 0 0059 (10) | 63 14 ± 6 51 (9)
200 + 1,000 | 0 0186 ± 0 0011 (10) | 0 0485 ± 0 0019 (10) | 01221 ± 0 0070 (10) | 59 38 ± 6 49 (9)
400 + 0 | 0 0205 ± 0 0007 (10) | 0 0486 ± 0 0015 (10) | 0 1148 ± 0 0065 (10) | 62 90 ± 4 25 (9)
400 + 250 | 0 0204 ± 0 0012 (10) | 0 0504 ± 0 0016 (10) | 0 1205 ± 0 0028 (10) | 58 82 ± 5 10(9)
400 + 500 | 0 0199 ± 0 0010 (10) | 0 0524 ± 0 0015 (10) | 0 1225 ± 0 0052 (10) | 50 67 ± 7 29 (9)
400 + 1,000 | 0 0177 ± 0 0011 (10) | 0 0470 ± 0 0016 (10) | 0 1190 ± 0 0065 (10) | 55 48 ± 6 91 (9)
Dose^a^ | Sperm per mg Cauda (×10^3^) | Sperm per Cauda (×10^6^) | Spermatids per mg Testis (×10^3^) | Spermatids per Testis (×10^6^)
0 + 0 | 1016 4 ± 90 79(9) | 20 7 ± 1 65 (9) | 248 87 ± 10 64 (9) | 25 58 ± 1 14 (9)
0 + 250 | 1052 5 ± 106 99 (10) | 20 4 ± 1 55 (10) | 209 57 ± 8 95 (10) | 22 48 ± 0 63 (10)
0 + 500 | 1099 4 ± 91 31 (10) | 21 5 ± 1 57 (10) | 231 59 ± 11 73 (10) | 22 56 ± 1 41 (10)
0 + 1,000 | 1109 1 ± 83 83 (10) | 21 6 ± 1 87 (10) | 239 44 ± 21 24 (10) | 24 61 ± 2 34 (10)
200 + 0 | 1102 9 ± 82 75 (10) | 23 1 ± 2 14(10) | 234 54 ± 15 88 (10) | 25 52 ± 2 40 (10)
200 + 250 | 1145 2 ± 133 07 (10) | 23 2 ± 2 60 (10) | 212 45 ± 12 13 (10) | 21 40 ± 1 87 (10)
200 + 500 | 1020 7 ± 58 02 (10) | 19 9 ± 1 47 (10) | 222 71 ± 18 27 (10) | 23 16 ± 2 25 (10)
200 + 1,000 | 1108 7 ± 71 56(10) | 20 6 ± 1 78 (10) | 242 77 ± 17 11 (10) | 24 16 ± 1 71 (10)
400 + 0 | 1149 4 ± 91 09 (10) | 23 2 ± 1 64 (10) | 256 16 ± 14 88 (10) | 23 36 ± 1 33 (10)
400 + 250 | 1115 5 ± 100 35 (10) | 22 6 ± 2 32 (10) | 230 70 ± 16 07 (10) | 23 44 ± 2 07 (10)
400 + 500 | 1147 1 ± 87 44 (10) | 23 2 ± 2 60 (10) | 232 47 ± 15 04 (10) | 23 97 ± 1 52 (10)
400 + 1,000 | 1015 1 ± 45 04 (10) | 17 7 ± 0 80 (10) | 236 86 ± 10 13 (10) | 24 91 ± 1 74 (10)

a AZT + clarithromycin in mg/kg per day

b All values presented as group mean ± standard error (number of animals providing data)

NOTE A two-way analysis of variance indicates no significant AZT or clarithromycin effect and no significant interaction

## Other NIEHS Reports and Publications on the Toxicology of AIDS Therapeutics

National Institute of Environmental Health Sciences (NIEHS) (1997). Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 1. NIH Publication No. 97-3938. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1998). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT), Trimethoprim (TMP)/Sulfamethoxazole (SMX), and Folinic Acid Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No.2. NIH Publication No. 99-3940. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1999). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Isoniazid Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No.3. NIH Publication No. 99-3941. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Rifabutin Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No.4. NIH Publication No. 00-3948. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Subchronic Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Pyrazinamide Combinations Administered by Gavage to B6C3F_1_ Mice. NIEHS AIDS Therapeutics Toxicity Report No.5. NIH Publication No. 00-3949. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2001). Subchronic Toxicity Studies of 3-Azido-3′-deoxythymidine (AZT)/Rifampicin Combinations Administered by Gavage to B6C3F_1_ Mice. NIEHS AIDS Therapeutics Toxicity Report No. 6. NIH Publication No. 01-4401. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2002). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT) and Pyrazinamide Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No.7. NIH Publication No. 02-4408. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2002). 13-Week Toxicity Study of 3′-Azido-3′ deoxythymidine (AZT) and Isoniazid Combinations Administered by Gavage to B6C3F_1_ Mice. NIEHS AIDS Therapeutics Toxicity Report No.8. NIH Publication No. 02-4411. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
Rao, G.N., Collins, B.J., Giles, H.D., Heath, J.E., Foley, J.F., May, R.D., and Buckley, L.A. (1996). Carcinogenicity of 2′,3′-dideoxycytidine in mice. Cancer Res. 56, 4666–4672.8840982
Rao, G.N., Lindamood, C., Heath, J.E., Farnell, D.R., and Giles, H.D. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Sanders, V.M., Elwell, M.R., Heath, J.E., Collins, B.J., Dunnick, J.K., Rao, G.N., Prejean, D., Lindamood, C., and Irwin, R.D. (1995). Induction of thymic lymphoma in mice administered the dideoxynucleoside ddC. Fundam. Appl. Toxicol. 27, 263–269.8529822
Zhuang, S.-M., Eklund, L.K., Cochran, C., Rao, G.N., Wiseman, R.W., and Soderkvist, P. (1996). Allelotype analysis of 2′,3′-dideoxycytidine- and 1,3-butadiene-induced lymphomas in B6C3F_1_ mice. Cancer Res. 56, 3338–3343.8764131