# APPENDIX C Necropsy Findings

TABLE C1 Summary of Principal Necropsy Findings for Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Male Mice

Dose^a^ | 0 + 0 | 200 + 0 | 400 + 0 | 0 + 250 | 0 + 500 | 0 + 1,000
n^b^ | 10 | 10 | 10 | 10 | 10 | 10
Lesion | Incidence
Stomach, dilatation and/or mottled | 0 | 0 | 0 | 0 | 0 | 0
Carcass, pale | 0 | 0 | 0 | 0 | 0 | 0
Kidney, mottled and/or pale | 0 | 0 | 0 | 0 | 0 | 0
Spleen, small | 0 | 0 | 0 | 0 | 0 | 0
Thymus, small | 0 | 0 | 1 | 0 | 1 | 0
Bone, deformity | 0 | 0 | 0 | 0 | 1 | 1
Dose^a^ | 200 + 250 | 200 + 500 | 200 + 1,000 | 400 + 250 | 400 + 500 | 400 + 1,000
n^b^ | 10 | 10 | 10 | 10 | 10 | 10
Lesion | Incidence
Stomach, dilatation and/or mottled | 0 | 0 | 0 | 0 | 0 | 2
Carcass, pale | 0 | 0 | 0 | 0 | 0 | 1
Kidney, mottled and/or pale | 1 | 0 | 1 | 0 | 1 | 0
Spleen, small | 1 | 0 | 0 | 0 | 0 | 1
Thymus, small | 0 | 0 | 2 | 1 | 2 | 3
Bone, deformity | 0 | 0 | 1 | 0 | 0 | 1

a AZT + clarithromycin in mg/kg per day

b n = number of animals examined in group

Female-A Mice

Dose^a^ | 0 + 0 | 200 + 0 | 400 + 0 | 0 + 250 | 0 + 500 | 0 + 1,000
n^b^ | 20 | 20 | 20 | 20 | 20 | 20
Lesion | Incidence
Stomach, dilatation and/or mottled | 0 | 0 | 0 | 0 | 0 | 0
Carcass, pale | 0 | 1 | 0 | 0 | 1 | 1
Kidney, mottled and/or pale | 0 | 0 | 0 | 0 | 0 | 2
Liver, enlarged | 0 | 0 | 0 | 0 | 0 | 1
Spleen, small | 0 | 0 | 0 | 0 | 0 | 0
Spleen, enlarged | 0 | 0 | 1 | 0 | 0 | 3
Thymus, small | 0 | 0 | 0 | 0 | 2 | 1
Bone, deformity | 0 | 0 | 0 | 0 | 1 | 0
Dose^a^ | 200 + 250 | 200 + 500 | 200 + 1,000 | 400 + 250 | 400 + 500 | 400 + 1,000
n^b^ | 20 | 20 | 20 | 20 | 20 | 20
Lesion | Incidence
Stomach, dilatation and/or mottled | 0 | 1 | 4 | 2 | 2 | 4
Carcass, pale | 0 | 0 | 1 | 1 | 4 | 4
Kidney, mottled and/or pale | 0 | 0 | 2 | 0 | 3 | 1
Liver, enlarged | 0 | 0 | 0 | 0 | 0 | 0
Spleen, small | 0 | 0 | 0 | 0 | 1 | 0
Spleen, enlarged | 0 | 0 | 2 | 0 | 0 | 1
Thymus, small | 0 | 0 | 2 | 1 | 1 | 1
Bone, deformity | 0 | 0 | 2 | 1 | 1 | 0

a AZT + clarithromycin m mg/kg per day

b n = number of animals examined in group

Female-B Mice

Dose^a^ | 0 + 0 | 200 + 0 | 400 + 0 | 0 + 250 | 0 + 500 | 0 + 1,000
n^b^ | 15 | 15 | 16 | 15 | 14 | 15
Lesion | Incidence
Liver, pale | 0 | 0 | 0 | 0 | 0 | 0
Spleen, enlarged | 0 | 0 | 0 | 0 | 0 | 0
Bone, deformity | 0 | 0 | 0 | 0 | 0 | 0
Dose^a^ | 200 + 250 | 200 + 500 | 200 + 1,000 | 400 + 250 | 400 + 500 | 400 + 1,000
n^b^ | 15 | 15 | 14 | 14 | 16 | 15
Lesion | Incidence
Liver, pale | 0 | 0 | 0 | 0 | 1 | 0
Spleen, enlarged | 0 | 1 | 1 | 0 | 1 | 4
Bone, deformity | 0 | 0 | 0 | 1 | 0 | 0

a AZT + clarithromycin in mg/kg per day

b n = number of animals examined in group