# APPENDIX B Clinical Pathology

List of Abbreviations
WBC: White blood cells
RBC: Red blood cells
Hgb: Hemoglobin
Hct: Hematocrit
MCV: Mean corpuscular volume
MCH: Mean corpuscular hemoglobin
MCHC: Mean corpuscular hemoglobin concentration
Plt: Platelets
Retic: Reticulocytes
Neut: Neutrophils
Lymph: Lymphocytes
Mono: Monocytes
Eos: Eosinophils
Baso: Basophils
LUC: Large unstained cells
RDW: Red cell distribution width
BUN: Blood urea nitrogen
Crea: Creatinine
ALP: Alkaline phosphatase
ALT: Alanine aminotransferase
AST: Aspartate aminotransferase
BilA: Total bile acids

TABLE B1 Summary of Hematology Parameters for Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Male Mice

| WBC 10^3^/μL | RBC 10^6^/μL | Hgb g/dL | Hct % | MCV fL | MCH pg | MCHC g/dL | Plt 10^3^/μL
0 + 0 mg/kg per day^a^
Mean | 6 10 | 10 34 | 16 4 | 47 9 | 46 5 | 15 9 | 34 2 | 838
SD | 1 469 | 0 795 | 1 14 | 3 22 | 2 41 | 0 72 | 0 64 | 253 3
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 0 mg/kg per day
Mean | 5 74 | 9 29 | 15 4 | 46 6 | 50 3^*^ | 16 7 | 33 2 | 920
SD | 1 642 | 0 936 | 1 25 | 3 85 | 2 64 | 0 70 | 0 90 | 158 9
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 0 mg/kg per day
Mean | 4 87 | 7 95^**^ | 13 8^**^ | 41 6^*^ | 52 4^**^ | 17 5^**^ | 33 3 | 1,131
SD | 1 072 | 1 009 | 1 47 | 4 52 | 1 90 | 0 54 | 0 58 | 230 2
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 250 mg/kg per day
Mean | 6 91 | 9 84 | 16 0 | 47 1 | 47 9 | 16 2 | 33 9 | 922
SD | 2 109 | 0 503 | 0 97 | 2 84 | 1 86 | 0 58 | 0 74 | 107 7
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 500 mg/kg per day
Mean | 7 29 | 9 71 | 15 7 | 45 6 | 47 3 | 16 2 | 34 5 | 983
SD | 1 549 | 0 956 | 0 81 | 2 70 | 3 51 | 1 07 | 0 81 | 202 1
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 1,000 mg/kg per day
Mean | 7 14 | 9 80 | 15 9 | 46 3 | 47 3 | 16 2 | 34 3 | 1,034
SD | 2 872 | 0 623 | 1 04 | 2 75 | 1 36 | 0 26 | 1 07 | 345 4
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 250 mg/kg per day
Mean | 5 07 | 8 30^**^ | 14 3^*^ | 42 2 | 51 0^**^ | 17 3^**^ | 33 8 | 1,236
SD | 2 274 | 0 794 | 1 17 | 3 79 | 2 61 | 0 88 | 0 68 | 282 7
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 500 mg/kg per day
Mean | 5 02 | 7 82^**^ | 13 3^**^ | 39 6^**^ | 50 6^**^ | 17 1^**^ | 33 7 | 1,095
SD | 1 679 | 1 097 | 1 93 | 6 07 | 2 65 | 0 59 | 0 81 | 280 7
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 1,000 mg/kg per day
Mean | 5 29 | 7 56^**^ | 12 7^**^ | 37 2^**^ | 48 9 | 16 7 | 34 2 | 1,141
SD | 1 764 | 0 947 | 1 93 | 6 67 | 3 65 | 0 71 | 1 45 | 165 3
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 250 mg/kg per day
Mean | 4 31 | 6 94^**^ | 11 8^**^ | 35 1^**^ | 50 6^*^ | 17 0^**^ | 33 7 | 1,299
SD | 1 368 | 1 081 | 1 88 | 6 15 | 2 16 | 0 67 | 0 96 | 306 7
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 500 mg/kg per day
Mean | 5 75 | 7 02^**^ | 11 9^**^ | 35 0^**^ | 49 7 | 16 9^*^ | 34 0 | 1,412
SD | 1 747 | 1 244 | 2 24 | 7 06 | 2 81 | 0 64 | 0 82 | 549 4
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 1,000 mg/kg per day
Mean | 5 58 | 5 95^**^ | 9 9^**^ | 28 5^**^ | 47 5 | 16 5 | 34 9 | 1,343
SD | 3 336 | 1 245 | 2 39 | 7 83 | 4 29 | 0 93 | 1 40 | 578 5
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
| Retie 10^5^/μL | Neut 10^3^/μL | Lymph 10^3^/μL | Mono 10^3^/μL | Eos 10^3^/μL | Baso 10^3^/μL | LUC 10^3^/μL | RDW %
0 + 0 mg/kg per day
Mean | 4 0 | 1 00 | 4 76 | 0 09 | 0 16 | 0 03 | 0 07 | 13 9
SD | 0 64 | 0 582 | 1 011 | 0 031 | 0 090 | 0 018 | 0 073 | 0 80
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 0 mg/kg per day
Mean | 4 1 | 0 75 | 4 66 | 0 08 | 0 17 | 0 02 | 0 06 | 19 8^**^
SD | 0 75 | 0 439 | 1 529 | 0 032 | 0 097 | 0 012 | 0 038 | 2 38
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 0 mg/kg per day
Mean | 4 0 | 0 60 | 3 98 | 0 10 | 0 13 | 0 01 | 0 07 | 22 3^**^
SD | 1 66 | 0 289 | 0 894 | 0 055 | 0 081 | 0 008 | 0 039 | 2 29
n | 9 | 10 | 10 | 10 | 10 | 10 | 8 | 10
0 + 250 mg/kg per day
Mean | 4 7 | 0 89 | 5 71 | 0 09 | 0 14 | 0 03 | 0 06 | 14 3
SD | 2 34 | 0 338 | 1 782 | 0 036 | 0 045 | 0 011 | 0 029 | 0 78
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 500 mg/kg per day
Mean | 4 1 | 1 18 | 5 69 | 0 11 | 0 21 | 0 03 | 0 09 | 14 3
SD | 0 70 | 0 425 | 1 425 | 0 051 | 0 138 | 0 016 | 0 043 | 0 49
n | 9 | 10 | 10 | 10 | 10 | 10 | 9 | 10
0 + 1,000 mg/kg per day
Mean | 4 3 | 1 07 | 5 49 | 0 12 | 0 27 | 0 03 | 0 16 | 14 5
SD | 0 62 | 0 522 | 2 313 | 0 057 | 0 171 | 0 018 | 0 200 | 0 43
n | 9 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 250 mg/kg per day
Mean | 3 4 | 0 68 | 4 04 | 0 08 | 0 20 | 0 02 | 0 06 | 21 7^**^
SD | 1 09 | 0 677 | 1 760 | 0 039 | 0 108 | 0 009 | 0 038 | 1 82
n | 9 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 500 mg/kg per day
Mean | 3 2 | 0 77 | 3 93 | 0 09 | 0 17 | 0 01 | 0 05 | 23 1^**^
SD | 1 16 | 0 773 | 1 351 | 0 071 | 0 094 | 0 007 | 0 025 | 2 69
n | 9 | 10 | 10 | 10 | 10 | 10 | 9 | 10
200 + 1,000 mg/kg per day
Mean | 3 9 | 0 59 | 4 30 | 0 08 | 0 20 | 0 02 | 0 11 | 21 5^**^
SD | 1 76 | 0 259 | 1 460 | 0 045 | 0 164 | 0 008 | 0 085 | 4 40
n | 8 | 10 | 10 | 10 | 10 | 10 | 9 | 10
400 + 250 mg/kg per day
Mean | 2 6 | 0 41 | 3 65 | 0 06 | 0 12 | 0 01 | 0 06 | 24 2^**^
SD | 1 22 | 0 211 | 1 179 | 0 027 | 0 044 | 0 005 | 0 033 | 2 11
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 500 mg/kg per day
Mean | 4 1 | 0 76 | 4 71 | 0 08 | 0 12 | 0 01 | 0 08 | 24 2^**^
SD | 2 86 | 0 658 | 1 712 | 0 039 | 0 076 | 0 011 | 0 047 | 4 22
n | 9 | 10 | 10 | 10 | 10 | 10 | 7 | 10
400 + 1,000 mg/kg per day
Mean | 2 4 | 1 17 | 4 01 | 0 12 | 0 19 | 0 02 | 0 10 | 21 7^**^
SD | 1 97 | 1 580 | 2 595 | 0 131 | 0 144 | 0 015 | 0 076 | 6 96
n | 9 | 10 | 10 | 10 | 10 | 10 | 8 | 10

a AZT + clarithromycin

* Significantly different (P<0 05) from the control by Dunnett’s test

** Significantly different (P<0 01) from the control by Dunnett’s test

Female-A Mice

| WBC 10^3^/μL | RBC 10^6^/μL | Hgb g/dL | Hct % | MCV fL | MCH pg | MCHC g/dL | Plt 10^3^/μL
0 + 0 mg/kg per day^a^
Mean | 5 92 | 8 57 | 14 4 | 42 0 | 49 0 | 16 8 | 34 4 | 1,034
SD | 1 226 | 0 553 | 1 43 | 3 54 | 2 78 | 1 04 | 1 26 | 191 1
n | 19 | 19 | 19 | 19 | 19 | 19 | 19 | 19
200 + 0 mg/kg per day
Mean | 5 23 | 7 60 | 14 3 | 42 1 | 55 5^**^ | 18 8^**^ | 34 0 | 1,126
SD | 1 561 | 0 664 | 1 08 | 3 38 | 2 92 | 0 98 | 1 27 | 226 1
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
400 + 0 mg/kg per day
Mean | 6 75 | 7 75 | 14 2 | 42 6 | 55 3^**^ | 18 4^**^ | 33 3 | 1,065
SD | 1 431 | 1 018 | 1 55 | 4 46 | 3 62 | 0 84 | 1 49 | 195 7
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
0 + 250 mg/kg per day
Mean | 7 47 | 8 78 | 14 8 | 43 5 | 49 6 | 16 8 | 33 9 | 1,134
SD | 1 946 | 0 527 | 1 47 | 3 03 | 1 51 | 0 83 | 1 50 | 248 0
n | 11 | 11 | 11 | 11 | 11 | 11 | 11 | 11
0 + 500 mg/kg per day
Mean | 7 99 | 8 89 | 14 5 | 42 5 | 47 8 | 16 3 | 34 2 | 1,076
SD | 3 106 | 1 187 | 2 17 | 5 82 | 1 07 | 0 52 | 1 13 | 212 2
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
0 + 1,000 mg/kg per day
Mean | 12 74^**^ | 9 21 | 14 8 | 43 9 | 47 7 | 16 1 | 33 8 | 821
SD | 7 679 | 0 784 | 1 70 | 4 24 | 2 65 | 0 79 | 1 95 | 275 6
n | 11 | 11 | 11 | 11 | 11 | 11 | 11 | 11
200 + 250 mg/kg per day
Mean | 5 61 | 6 59^**^ | 12 5 | 38 0 | 57 6^**^ | 19 1^**^ | 33 2 | 1,442^**^
SD | 1 022 | 0 844 | 1 64 | 5 65 | 5 44 | 1 29 | 1 89 | 335 2
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
200 + 500 mg/kg per day
Mean | 6 23 | 6 66^**^ | 13 0 | 39 6 | 59 7^**^ | 19 6^**^ | 32 8 | 1,332
SD | 2 350 | 0 857 | 1 48 | 3 94 | 4 14 | 1 13 | 1 15 | 342 9
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
200 + 1,000 mg/kg per day
Mean | 6 47 | 6 01^**^ | 11 0^**^ | 32 5^**^ | 53 0 | 18 0^**^ | 34 3 | 1,386^*^
SD | 3 000 | 1 244 | 2 83 | 9 85 | 6 92 | 1 35 | 2 54 | 338 6
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
400 + 250 mg/kg per day
Mean | 5 59 | 5 22^**^ | 9 7^**^ | 29 5^**^ | 53 6^*^ | 18 0^*^ | 34 0 | 1,758^**^
SD | 1 505 | 2 183 | 4 46 | 14 82 | 8 73 | 1 69 | 3 14 | 653 2
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
400 + 500 mg/kg per day
Mean | 4 36 | 2 45^**^ | 4 0^**^ | 11 0^**^ | 44 5 | 16 4 | 36 9^**^ | 1,982^**^
SD | 1 158 | 0 692 | 1 22 | 3 43 | 1 43 | 0 95 | 2 16 | 808 8
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
400 + 1,000 mg/kg per day
Mean | 3 87 | 3 66^**^ | 6 3^**^ | 17 6^**^ | 46 8 | 17 0 | 36 6^*^ | 1,645^**^
SD | 1 655 | 2 196 | 3 93 | 11 85 | 5 77 | 1 51 | 1 78 | 455 6
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
| Retic 10^5^/μL | Neut 10^3^/μL | Lymph 10^3^/μL | Mono 10^3^/μL | Eos 10^3^/μL | Baso 10^3^/μL | LUC 10^3^/μL | RDW %
0 + 0 mg/kg per day
Mean | 3 9 | 1 71 | 3 92 | 0 09 | 0 10 | 0 02 | 0 07 | 16 0
SD | 1 16 | 0 589 | 1 033 | 0 028 | 0 036 | 0 008 | 0 030 | 1 19
n | 19 | 19 | 19 | 19 | 19 | 19 | 19 | 19
200 + 0 mg/kg per day
Mean | 3 9 | 1 16 | 3 76 | 0 09 | 0 14 | 0 01 | 0 07 | 19 9
SD | 1 34 | 0 477 | 1 171 | 0 048 | 0 141 | 0 009 | 0 041 | 1 63
n | 19 | 20 | 20 | 20 | 20 | 20 | 18 | 20
400 + 0 mg/kg per day
Mean | 4 0 | 1 13 | 5 21^*^ | 0 12 | 0 18 | 0 02 | 0 09 | 21 1^*^
SD | 1 23 | 0 307 | 1 461 | 0 035 | 0 065 | 0 010 | 0 027 | 1 75
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
0 + 250 mg/kg per day
Mean | 3 9 | 2 33 | 4 72 | 0 12 | 0 15 | 0 02 | 0 13 | 15 8
SD | 1 02 | 0 907 | 1 323 | 0 032 | 0 048 | 0 010 | 0 072 | 1 18
n | 9 | 11 | 11 | 11 | 11 | 11 | 11 | 11
0 + 500 mg/kg per day
Mean | 3 4 | 2 57 | 4 97 | 0 13 | 0 18 | 0 03 | 0 12 | 15 4
SD | 1 27 | 2 055 | 1 200 | 0 086 | 0 116 | 0 009 | 0 086 | 0 67
n | 11 | 12 | 12 | 12 | 12 | 12 | 12 | 12
0 + 1,000 mg/kg per day
Mean | 3 3 | 5 71^**^ | 5 89^**^ | 0 22^**^ | 0 46^**^ | 0 06^**^ | 0 40^**^ | 15 4
SD | 1 54 | 6 298 | 1 768 | 0 124 | 0 306 | 0 062 | 0 530 | 0 84
n | 11 | 11 | 11 | 11 | 11 | 11 | 11 | 11
200 + 250 mg/kg per day
Mean | 4 4 | 1 36 | 3 92 | 0 09 | 0 13 | 0 01 | 0 11 | 25 8^**^
SD | 2 59 | 0 488 | 0 758 | 0 031 | 0 066 | 0 006 | 0 050 | 5 36
n | 20 | 20 | 20 | 20 | 20 | 20 | 19 | 20
200 + 500 mg/kg per day
Mean | 4 1 | 1 70 | 4 10 | 0 11 | 0 20 | 0 02 | 0 10 | 26 7^**^
SD | 1 41 | 1 577 | 1 089 | 0 081 | 0 149 | 0 011 | 0 045 | 5 03
n | 19 | 20 | 20 | 20 | 20 | 20 | 19 | 20
200 + 1,000 mg/kg per day
Mean | 4 0 | 1 75 | 4 18 | 0 10 | 0 23^*^ | 0 02 | 0 20 | 24 6^**^
SD | 2 48 | 2 210 | 1 049 | 0 084 | 0 157 | 0 013 | 0 172 | 7 00
n | 19 | 20 | 20 | 20 | 20 | 20 | 19 | 20
400 + 250 mg/kg per day
Mean | 3 5 | 0 98 | 4 27 | 0 09 | 0 14 | 0 01 | 0 11 | 25 4^**^
SD | 3 01 | 0 651 | 1 316 | 0 061 | 0 089 | 0 008 | 0 051 | 5 74
n | 12 | 12 | 12 | 12 | 12 | 12 | 11 | 12
400 + 500 mg/kg per day
Mean | 0 6^**^ | 0 23 | 3 97 | 0 02^*^ | 0 04 | 0 01 | 0 08 | 16 1
SD | 0 52 | 0 231 | 1 037 | 0 016 | 0 053 | 0 006 | 0 056 | 5 66
n | 11 | 12 | 12 | 12 | 12 | 12 | 11 | 12
400 + 1,000 mg/kg per day
Mean | 1 9 | 0 54 | 3 09 | 0 05 | 0 11 | 0 01 | 0 09 | 19 3
SD | 2 91 | 0 784 | 0 888 | 0 041 | 0 158 | 0 006 | 0 080 | 9 14
n | 10 | 10 | 10 | 10 | 10 | 10 | 8 | 10

a AZT + clarithromycin

* Significantly different (P<0 05) from the control by Dunnett’s test

** Significantly different (P<0 01) from the control by Dunnett’s test

Female-B Mice

| WBC 10^3^/μL | RBC 10^6^/μL | Hgb g/dL | Hct % | MCV fL | MCH Pg | MCHC g/dL | Plt 10^3^/μL
0 + 0 mg/kg per day^a^
Mean | 4 92 | 8 26 | 14 2 | 42 5 | 51 6 | 17 2 | 33 3 | 1,100
SD | 1 615 | 0 658 | 1 11 | 2 57 | 2 28 | 0 66 | 0 88 | 253 2
n | 14 | 14 | 14 | 14 | 14 | 14 | 14 | 14
200 + 0 mg/kg per day
Mean | 5 17 | 7 94 | 14 5 | 43 0 | 54 4^**^ | 18 3^**^ | 33 7 | 1,093
SD | 1 277 | 0 840 | 1 34 | 3 07 | 2 35 | 0 65 | 1 44 | 328 9
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
400 + 0 mg/kg per day
Mean | 4 72 | 7 69 | 14 1 | 42 0 | 54 7^**^ | 18 3^**^ | 33 5 | 1,089
SD | 1 123 | 0 367 | 0 52 | 1 42 | 1 83 | 0 60 | 0 70 | 196 0
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
0 + 250 mg/kg per day
Mean | 5 40 | 8 30 | 14 5 | 43 3 | 52 3 | 17 5 | 33 5 | 1,146
SD | 1 376 | 0 488 | 0 71 | 2 48 | 2 55 | 0 60 | 1 27 | 308 7
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
0 + 500 mg/kg per day
Mean | 5 00 | 8 88 | 15 4 | 45 1 | 50 9 | 17 3 | 34 0 | 1,121
SD | 1 435 | 0 645 | 1 51 | 3 54 | 2 26 | 0 76 | 1 58 | 287 2
n | 13 | 13 | 13 | 13 | 13 | 13 | 13 | 13
0 + 1,000 mg/kg per day
Mean | 5 24 | 8 80 | 15 4 | 45 6 | 51 8 | 17 5 | 33 8 | 1,196
SD | 1 492 | 0 482 | 0 92 | 2 64 | 1 67 | 0 59 | 0 90 | 364 0
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
200 + 250 mg/kg per day
Mean | 5 53 | 7 92 | 14 6 | 43 7 | 55 3^**^ | 18 5^**^ | 33 4 | 1,303
SD | 2 071 | 0 563 | 1 02 | 3 12 | 2 48 | 0 72 | 1 31 | 166 6
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
200 + 500 mg/kg per day
Mean | 5 47 | 8 16 | 15 2 | 45 2 | 55 4^**^ | 18 7^**^ | 33 7 | 1,193
SD | 1 693 | 0 809 | 1 66 | 4 37 | 2 19 | 0 78 | 1 27 | 295 7
n | 14 | 14 | 14 | 14 | 14 | 14 | 14 | 14
200 + 1,000 mg/kg per day
Mean | 5 30 | 8 41 | 15 4 | 45 9 | 54 8^**^ | 18 4^**^ | 33 6 | 1,066
SD | 1 278 | 0 892 | 1 37 | 4 16 | 2 72 | 0 77 | 0 87 | 335 7
n | 14 | 14 | 14 | 14 | 14 | 14 | 14 | 14
400 + 250 mg/kg per day
Mean | 6 03 | 8 14 | 15 2 | 43 7 | 53 7 | 18 6^**^ | 34 7 | 1,185
SD | 1 384 | 0 731 | 1 36 | 4 07 | 2 45 | 0 81 | 0 67 | 286 6
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
400 + 500 mg/kg per day
Mean | 5 01 | 8 73 | 16 2 | 47 3 | 54 3^*^ | 18 5^*^ | 34 1 | 1,149
SD | 1 555 | 0 790 | 1 29 | 3 78 | 2 01 | 0 72 | 0 77 | 339 2
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
400 + 1,000 mg/kg per day
Mean | 5 96 | 8 12 | 15 0 | 44 2 | 54 5^**^ | 18 5^**^ | 33 9 | 1,105
SD | 2 008 | 1 214 | 2 25 | 6 58 | 2 52 | 0 50 | 0 84 | 386 0
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
| Retic 10^5^/μL | Neut 10^3^/μL | Lymph 10^3^/μL | Mono 10^3^/μL | Eos 10^3^/μL | Baso 10^3^/μL | LUC 10^3^/μL | RDW %
0 + 0 mg/kg per day
Mean | 4 4 | 1 06 | 3 55 | 0 08 | 0 16 | 0 01 | 0 07 | 17 1
SD | 1 43 | 0 619 | 0 949 | 0 042 | 0 128 | 0 008 | 0 053 | 1 49
n | 13 | 14 | 14 | 14 | 14 | 14 | 12 | 14
200 + 0 mg/kg per day
Mean | 6 8 | 1 22 | 3 62 | 0 08 | 0 17 | 0 02 | 0 07 | 19 9^**^
SD | 2 34 | 0 489 | 1 045 | 0 023 | 0 118 | 0 009 | 0 038 | 1 81
n | 14 | 15 | 15 | 15 | 15 | 15 | 15 | 15
400 + 0 mg/kg per day
Mean | 6 0 | 0 99 | 3 45 | 0 08 | 0 13 | 0 01 | 0 06 | 21 4^**^
SD | 1 57 | 0 380 | 0 934 | 0 027 | 0 072 | 0 008 | 0 031 | 1 61
n | 16 | 16 | 16 | 16 | 16 | 16 | 15 | 16
0 + 250 mg/kg per day
Mean | 4 7 | 1 12 | 4 00 | 0 08 | 0 12 | 0 01 | 0 09 | 17 4
SD | 1 35 | 0 589 | 1 098 | 0 026 | 0 051 | 0 007 | 0 059 | 1 04
n | 15 | 15 | 15 | 15 | 15 | 15 | 13 | 15
0 + 500 mg/kg per day
Mean | 4 1 | 0 92 | 3 81 | 0 08 | 0 12 | 0 01 | 0 07 | 16 3
SD | 1 35 | 0 401 | 1 073 | 0 038 | 0 056 | 0 007 | 0 048 | 1 15
n | 12 | 13 | 13 | 13 | 13 | 13 | 12 | 13
0 + 1,000 mg/kg per day
Mean | 3 8 | 1 10 | 3 84 | 0 08 | 0 14 | 0 01 | 0 07 | 16 7
SD | 1 29 | 0 651 | 0 905 | 0 052 | 0 131 | 0 011 | 0 055 | 1 23
n | 15 | 15 | 15 | 15 | 15 | 15 | 14 | 15
200 + 250 mg/kg per day
Mean | 6 2 | 1 22 | 4 02 | 0 07 | 0 12 | 0 02 | 0 07 | 22 0^**^
SD | 2 24 | 0 977 | 1 482 | 0 054 | 0 042 | 0 009 | 0 052 | 1 03
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
200 + 500 mg/kg per day
Mean | 4 7 | 0 99 | 4 10 | 0 08 | 0 21 | 0 02 | 0 08 | 22 8^**^
SD | 3 47 | 0 403 | 1 296 | 0 049 | 0 150 | 0 009 | 0 039 | 2 50
n | 14 | 14 | 14 | 14 | 14 | 14 | 13 | 14
200 + 1,000 mg/kg per day
Mean | 4 4 | 1 02 | 3 93 | 0 09 | 0 19 | 0 02 | 0 06 | 21 9^**^
SD | 2 69 | 0 555 | 0 978 | 0 043 | 0 106 | 0 011 | 0 036 | 2 69
n | 14 | 14 | 14 | 14 | 14 | 14 | 13 | 14
400 + 250 mg/kg per day
Mean | 5 4 | 1 17 | 4 44 | 0 09 | 0 20 | 0 02 | 0 10 | 22 3^**^
SD | 4 78 | 0 283 | 1 256 | 0 046 | 0 078 | 0 011 | 0 050 | 1 83
n | 12 | 12 | 12 | 12 | 12 | 12 | 12 | 12
400 + 500 mg/kg per day
Mean | 5 2 | 1 02 | 3 69 | 0 08 | 0 14 | 0 02 | 0 07 | 22 2^**^
SD | 2 24 | 0 665 | 1 168 | 0 065 | 0 065 | 0 008 | 0 046 | 2 09
n | 15 | 15 | 15 | 15 | 15 | 15 | 14 | 15
400 + 1,000 mg/kg per day
Mean | 5 0 | 1 02 | 4 53 | 0 09 | 0 17 | 0 03 | 0 14 | 23 9^**^
SD | 2 64 | 0 251 | 1 721 | 0 029 | 0 101 | 0 025 | 0 158 | 2 60
n | 15 | 15 | 15 | 15 | 15 | 15 | 13 | 15

a AZT + clarithromycin

* Significantly different (P<0 05) from the control by Dunnett’s test

** Significantly different (P<0 01) from the control by Dunnett’s test

TABLE B2 Summary of Clinical Chemistry Parameters for Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations Male Mice

Male Mice

| BUN mg/dL | Crea mg/dL | ALP U/L | ALT U/L | AST U/L | BilA μmol/L
0 + 0 mg/kg per day^a^
Mean | 24 2 | 0 40 | 60 | 32 | NA | 12
SD | 5 44 | 0 106 | 16 8 | 10 8 | NA | 10 3
n | 10 | 10 | 9 | 9 | 0 | 5
200 + 0 mg/kg per day
Mean | 23 8 | 0 41 | 62 | 31 | 82 | 23
SD | 4 31 | 0 113 | 9 9 | 6 3 | 12 7 | 13 5
n | 10 | 10 | 9 | 7 | 2 | 5
400 + 0 mg/kg per day
Mean | 26 6 | 0 46 | 44 | 31 | 95 | 15
SD | 4 07 | 0 214 | 11 6 | 8 1 | 39 7 | 13 8
n | 10 | 10 | 9 | 8 | 3 | 7
0 + 250 mg/kg per day
Mean | 23 6 | 0 39 | 54 | 35 | 104 | 26
SD | 3 05 | 0 077 | 15 0 | 11 0 | 6 0 | 13 8
n | 10 | 8 | 9 | 7 | 3 | 6
0 + 500 mg/kg per day
Mean | 24 1 | 0 42 | 53 | 35 | NA | 16
SD | 2 82 | 0 106 | 15 5 | 8 1 | NA | 13 5
n | 9 | 9 | 8 | 9 | 0 | 7
0 + 1,000 mg/kg per day
Mean | 23 1 | 0 44 | 47 | 58 | 62 | 20
SD | 6 32 | 0 185 | 10 8 | 33 2 | 4 9 | 25 6
n | 10 | 9 | 9 | 8 | 2 | 4
200 + 250 mg/kg per day
Mean | 24 2 | 0 38 | 45 | 29 | 63 | 24
SD | 5 56 | 0 099 | 10 5 | 5 4 | 2 8 | 17 9
n | 10 | 10 | 10 | 8 | 2 | 5
200 + 500 mg/kg per day
Mean | 21 1 | 0 39 | 53 | 35 | 112 | 26
SD | 3 40 | 0 083 | 19 4 | 11 5 | 62 0 | 12 2
n | 10 | 10 | 7 | 10 | 4 | 7
200 + 1,000 mg/kg per day
Mean | 21 1 | 0 36 | 51 | 82 | 109 | 25
SD | 3 92 | 0 101 | 20 7 | 84 2 | 46 1 | 16 3
n | 10 | 9 | 9 | 7 | 4 | 5
400 + 250 mg/kg per day
Mean | 31 8 | 0 47 | 59 | 28 | 65 | 16
SD | 10 81 | 0 203 | 20 0 | 8 7 | 9 3 | 14 4
n | 10 | 10 | 10 | 9 | 5 | 8
400 + 500 mg/kg per day
Mean | 21 0 | 0 39 | 52 | 41 | 74 | 13
SD | 3 15 | 0 094 | 11 5 | 25 3 | 15 6 | 6 7
n | 9 | 9 | 7 | 6 | 2 | 6
400 + 1,000 mg/kg per day
Mean | 24 7 | 0 44 | 55 | 44 | 129 | 18
SD | 4 31 | 0 077 | 23 2 | 13 1 | 89 1 | 14 3
n | 10 | 10 | 10 | 9 | 3 | 8

a AZT + clarithromycin

* Significantly different (P<0 05) from the control by Dunnett’s test

** Significantly different (P<0 01) from the control by Dunnett’s test

NA Not applicable

Female-A Mice

| BUN mg/dL | Crea mg/dL | ALP U/L | ALT U/L | AST U/L | BilA μmol/L
0 + 0 mg/kg per day^a^
Mean | 18 3 | 0 39 | 52 | 36 | 102 | 11
SD | 3 97 | 0 094 | 16 5 | 9 1 | 35 9 | 7 6
n | 19 | 19 | 18 | 19 | 12 | 16
200 + 0 mg/kg per day
Mean | 20 4 | 0 38 | 59 | 31 | 80 | 11
SD | 2 92 | 0 057 | 13 4 | 9 1 | 15 5 | 6 0
n | 20 | 20 | 20 | 19 | 11 | 14
400 + 0 mg/kg per day
Mean | 21 6 | 0 40 | 70 | 25 | 72 | 11
SD | 2 11 | 0 054 | 26 2 | 5 3 | 16 0 | 6 8
n | 12 | 11 | 12 | 11 | 7 | 11
0 + 250 mg/kg per day
Mean | 19 8 | 0 39 | 46 | 35 | 77 | 9
SD | 2 82 | 0 055 | 11 0 | 12 1 | 36 2 | 4 6
n | 11 | 11 | 11 | 10 | 5 | 7
0 + 500 mg/kg per day
Mean | 19 5 | 0 39 | 42 | 32 | 85 | 9
SD | 2 93 | 0 055 | 10 4 | 8 5 | 10 5 | 6 7
n | 12 | 12 | 11 | 11 | 6 | 8
0 + 1,000 mg/kg per day
Mean | 23 5^**^ | 0 45 | 53 | 52^*^ | 102 | 11
SD | 5 65 | 0 085 | 21 5 | 20 9 | 32 2 | 5 9
n | 10 | 9 | 10 | 8 | 4 | 6
200 + 250 mg/kg per day
Mean | 20 5 | 0 39 | 59 | 30 | 105 | 17
SD | 3 51 | 0 083 | 19 9 | 10 2 | 25 6 | 10 8
n | 20 | 20 | 20 | 20 | 17 | 18
200 + 500 mg/kg per day
Mean | 20 7 | 0 39 | 59 | 30 | 92 | 13
SD | 4 58 | 0 069 | 12 8 | 7 8 | 22 7 | 14 1
n | 20 | 20 | 19 | 20 | 16 | 18
200 + 1,000 mg/kg per day
Mean | 21 2 | 0 38 | 53 | 44 | 107 | 12
SD | 4 25 | 0 090 | 14 6 | 26 4 | 34 2 | 7 6
n | 19 | 19 | 18 | 17 | 10 | 14
400 + 250 mg/kg per day
Mean | 24 2^**^ | 0 40 | 79 | 26 | 76 | 12
SD | 5 62 | 0 034 | 41 6 | 6 4 | 18 3 | 4 2
n | 12 | 12 | 11 | 11 | 10 | 10
400 + 500 mg/kg per day
Mean | 27 8^**^ | 0 42 | 70 | 24^*^ | 72 | 19
SD | 3 35 | 0 064 | 14 6 | 10 3 | 38 4 | 7 0
n | 12 | 12 | 12 | 12 | 11 | 12
400 + 1,000 mg/kg per day
Mean | 24 4^**^ | 0 39 | 56 | 28 | 83 | 12
SD | 3 94 | 0 044 | 23 4 | 8 0 | 23 3 | 4 5
n | 10 | 9 | 10 | 9 | 9 | 9

a AZT + clarithromycin

* Significantly different (P<0 05) from the control by Dunnett’s test

** Significantly different (P<0 01) from the control by Dunnett’s test