# APPENDIX A Body Weights and Organ Weights

TABLE A1 Summary of Body Weights for Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Male Mice

Dose^a^ | Mean Body Weights^b^ on Study Day
Dose^a^ | 3 | 5 | 9 | 13 | 17 | 21 | 23
0 + 0 | 36 8 ± 1 7 | 36 7 ± 1 9 | 36 8 ± 1 9 | 36 3 ± 2 0 | 36 3 ± 2 0 | 36 6 ± 2 1 | 36 4 ± 1 8
200 + 0 | 37 2 ± 2 1 | 37 0 ± 2 3 | 37 1 ± 2 0 | 37 0 ± 1 9 | 37 1 ± 2 1 | 37 2 ± 1 9 | 37 0 ± 2 0
400 + 0 | 37 5 ± 1 3 | 36 9 ± 1 1 | 37 3 ± 1 6 | 36 9 ± 2 0 | 36 7 ± 2 6 | 37 3 ± 2 4 | 37 7 ± 2 3 (9)
0 + 250 | 37 1 ± 1 4 | 36 9 ± 1 4 | 37 3 ± 1 4 | 36 8 ± 2 1 | 37 2 ± 1 8 | 37 2 ± 1 5 | 37 9 ± 1 3
0 + 500 | 37 5 ± 1 8 | 37 3 ± 1 2 | 37 5 ± 1 4 | 37 3 ± 1 6 | 36 7 ± 1 5 | 37 8 ± 1 4 | 38 3 ± 1 3
0 + 1,000 | 37 1 ± 2 0 | 37 7 ± 2 0 | 37 6 ± 2 1 | 36 7 ± 1 4 | 36 3 ± 3 1 | 37 6 ± 2 2 | 37 7 ± 2 3
200 + 250 | 37 0 ± 1 0 | 37 3 ± 1 0 | 37 3 ± 1 4 | 37 1 ± 1 4 | 37 1 ± 1 2 | 36 6 ± 1 7 | 37 6 ± 1 8
200 + 500 | 36 7 ± 1 4 | 37 5 ± 1 6 | 37 6 ± 1 0 | 37 2 ± 1 7 | 37 2 ± 1 7 | 37 4 ± 1 4 | 38 2 ± 2 0
200 + 1,000 | 36 1 ± 3 2 | 38 0 ± 1 8 | 37 8 ± 1 9 | 36 9 ± 1 4 | 36 6 ± 1 2 | 36 2 ± 1 5 | 36 7 ± 1 8
400 + 250 | 36 9 ± 1 6 | 37 2 ± 1 5 | 37 7 ± 1 5 | 37 5 ± 1 4 | 37 3 ± 1 3 | 37 8 ± 0 8 | 38 3 ± 1 3
400 + 500 | 37 4 ± 1 3 | 37 6 ± 1 2 | 38 3 ± 1 6 | 37 8 ± 1 6 | 37 6 ± 1 6 | 36 9 ± 2 2 | 37 8 ± 1 6
400 + 1,000 | 37 4 ± 2 0 | 38 1 ± 1 9 | 38 7 ± 2 3 | 36 7 ± 2 2 | 36 1 ± 2 7 | 36 7 ± 3 0 | 37 2 ± 3 6

a AZT + clarithromycin in mg/kg per day

b Weight (grams) expressed as group mean ± standard deviation, n = 10 unless otherwise noted in parentheses

Female-A Mice

Dose^a^ | Mean Body Weights^b^ on Study Day
Dose^a^ | 0 | 4 | 12 | 16
0 + 0 | 29 4 ± 1 6 | 29 7 ± 1 2 | 29 0 ± 1 8 | 30 6 ± 1 6
200 + 0 | 30 0 ± 1 2 | 29 8 ± 1 6 | 28 6 ± 1 6 | 30 9 ± 1 7
400 + 0 | 29 4 ± 1 4 | 30 0 ± 1 3 | 29 2 ± 1 7 | 30 8 ± 1 6
0 + 250 | 29 7 ± 1 7 | 29 6 ± 1 6 | 29 8 ± 1 4 | 30 6 ± 1 4
0 + 500 | 29 8 ± 1 9 | 29 6 ± 1 5 | 30 2 ± 1 6 | 31 5 ± 1 7
0 + 1,000 | 30 8 ± 1 8 | 30 4 ± 2 2 | 30 0 ± 1 9 | 30 4 ± 2 8
200 + 250 | 30 2 ± 1 8 | 30 4 ± 1 7 | 30 3 ± 1 7 | 31 2 ± 1 6
200 + 500 | 30 4 ± 1 5 | 30 0 ± 1 8 | 30 6 ± 1 9 | 30 8 ± 1 6
200 + 1,000 | 30 4 ± 1 4 | 30 6 ± 1 5 | 30 2 ± 1 5 | 29 9 ± 2 3
400 + 250 | 30 0 ± 1 7 | 30 0 ± 1 6 | 29 9 ± 1 9 | 30 3 ± 1 6
400 + 500 | 30 5 ± 1 7 | 30 3 ± 1 9 | 30 0 ± 1 4(19) | 30 5 ± 1 7(19)
400 + 1,000 | 30 4 ± 1 4 | 30 8 ± 1 6 | 29 4 ± 1 5 | 29 2 ± 1 5
Dose^a^ | Mean Body Weights^b^ on Study Day
Dose^a^ | 20 | 23 | 26
0 + 0 | 35 1 ± 2 3 | 40 2 ± 2 9 | 48 0 ± 4 3
200 + 0 | 33 2 ± 3 1 | 36 4 ± 5 0 | 41 0 ± 7 8^*^
400 + 0 | 32 5 ± 2 4 | 34 6 ± 3 2^**^ | 37 2 ± 4 9^**^
0 + 250 | 34 4 ± 2 5 | 38 8 ± 4 2 | 46 2 ± 6 2
0 + 500 | 35 2 ± 3 0 | 39 3 ± 4 7 | 46 0 ± 7 4
0 + 1,000 | 34 5 ± 2 7 (19) | 37 2 ± 5 1 (19) | 42 9 ± 8 3 (19)
200 + 250 | 34 4 ± 3 0 | 37 8 ± 4 4 | 43 0 ± 6 8
200 + 500 | 33 2 ± 2 5 | 35 4 ± 3 6^**^ | 39 0 ± 5 4^**^
200 + 1,000 | 31 8 ± 3 2 | 33 4 ± 5 0^**^ | 35 8 ± 6 8^**^
400 + 250 | 32 8 ± 2 4 | 33 9 ± 3 8^**^ | 35 8 ± 5 7^**^
400 + 500 | 31 6 ± 2 3 (19) | 30 9 ± 2 7^**,▲^ (19) | 31 2 ± 3 6^**,▲▲^ (19)
400 + 1,000 | 29 4 ± 2 4^**^ | 29 6 ± 2 2^**,▲▲^ (19) | 29 7 ± 3 0^**,**,▲▲^ (19)

a AZT + clarithromycin in mg/kg per day

b Weight (grams) expressed as group mean ± standard deviation, n = 20 unless otherwise noted in parentheses

* P≤0 05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P≤0 01 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

▲ P≤0 05 compared to 400 + 0 group by Scheffe’s or Dunn’s test

▲▲ P≤0 01 compared to 400 + 0 group by Scheffe’s or Dunn’s test

Female-B Mice

Dose^a^ | n^b^ | Mean Body Weights^c^ on Day of Gestation
Dose^a^ | n^b^ | 0 | 8 | 12 | 15
0 + 0 | 15 | 30 7 ± 1 8^d^ | 35 0 ± 1 9 | 40 2 ± 4 1 | 48 3 ± 3 4(14)
200 + 0 | 14 | 30 0 ± 1 7 | 34 8 ± 2 1 | 40 1 ± 3 3 | 47 6 ± 5 3
400 + 0 | 16 | 28 6 ± 1 7 | 33 2 ± 2 1 | 39 4 ± 1 7 | 46 8 ± 2 2
0 + 250 | 15 | 28 5 ± 1 4 | 33 1 ± 1 8 | 39 5 ± 2 2 | 46 7 ± 3 3
0 + 500 | 12 | 28 8 ± 1 4 | 34 2 ± 2 3 (11) | 40 9 ± 3 1 (11) | 49 3 ± 3 5 (11)
0 + 1,000 | 14 | 29 2 ± 1 7^d^ | 34 2 ± 1 9 | 39 8 ± 2 6 | 47 3 ± 3 1
200 + 250 | 15 | 29 7 ± 1 2 | 34 4 ± 1 5 | 40 5 ± 2 1 | 47 6 ± 3 4
200 + 500 | 14 | 29 6 ± 1 1 | 33 8 ± 1 2 | 39 4 ± 2 4 | 45 2 ± 3 7
200 + 1,000 | 11 | 29 4 ± 1 7 | 34 4 ± 1 6 | 38 4 ± 1 8 | 44 1 ± 2 7
400 + 250 | 14 | 28 8 ± 1 5 | 34 6 ± 1 6 | 40 3 ± 2 7 | 44 1 ± 4 3
400 + 500 | 15 | 29 5 ± 1 5 | 34 9 ± 2 1 | 40 3 ± 3 7 | 44 7 ± 4 7
400 + 1,000 | 15 | 29 7 ± 1 9 | 34 7 ± 2 0 | 38 8 ± 2 6 | 42 1 ± 3 9^*^
Dose^a^ | n^b^ | Mean Body Weights^c^ on Day of Lactation
Dose^a^ | n^b^ | 0 | 1 | 4
0 + 0 | 15 | 36 6 ± 2 3 (14) | 36 7 ± 2 2 (14) | 42 9 ± 3 7 (14)
200 + 0 | 14 | 35 8 ± 2 3 | 36 1 ± 3 6 | 40 7 ± 3 5
400 + 0 | 16 | 35 3 ± 1 2 | 35 4 ± 1 6 | 40 8 ± 2 7
0 + 250 | 15 | 35 1 ± 2 0 | 35 5 ± 2 0 | 41 7 ± 2 9
0 + 500 | 12 | 35 7 ± 1 8 (11) | 37 1 ± 2 0 (11) | 41 5 ± 3 2 (11)
0 + 1,000 | 14 | 35 7 ± 2 2 | 36 1 ± 2 4(13) | 40 4 ± 3 5 (12)
200 + 250 | 15 | 35 9 ± 2 3 | 35 8 ± 2 6 | 40 2 ± 3 5 (14)
200 + 500 | 14 | 35 7 ± 1 7 (7) | 35 1 ± 2 5 (7) | 39 2 ± 2 6 (6)
200 + 1,000 | 11 | 33 2 ± 2 4 (8) | 32 8 ± 3 2 (5) | 34 4 ± 4 4^**^ (5)
400 + 250 | 14 | 35 7 ± 3 6 (6) | 34 8 ± 3 8 (5) | 35 0 ± 0 0 (2)
400 + 500 | 15 | 35 2 ± 10(4) | 34 2 ± 10(4) | 35 0 ± 5 6^*^ (4)
400 + 1,000 | 15 | (0) | (0) | (0)

a AZT + clarithromycin in mg/kg per day

b n = number of pregnant females in group unless otherwise noted in parentheses, dams with no surviving pups were excluded from lactation-period weights

c Weight (grams) expressed as group mean ± standard deviation

d One value not recorded

* P≤0 05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P≤0 01 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

TABLE A2 Summary of Organ Weights for Swiss (CD-1®) Mice in the Reproductive, Developmental, and General Toxicity Studies of AZT and Clarithromycin Combinations

Male Mice

Dose^a^ | n^b^ | Body Weight^c^ | Liver Weight^d^
Dose^a^ | n^b^ | Body Weight^c^ | Absolute | Relative
0 + 0 | 10 | 37 31 | 1 8870 ±0 1718 (NA) | 50 7 ± 5 4 (NA)
200 + 0 | 10 | 38 31 | 1 9110 ± 0 2618 (+1 3) | 49 8 ± 6 0 (−1 7)
400 + 0 | 10 | 38 33 | 1 9690 ± 0 2277 (+4 3) | 51 4 ± 5 2 (+1 3)
0 + 250 | 10 | 38 45 | 1 8560 ± 0 1841 (−1 6) | 48 3 ± 4 1 (−4 8)
0 + 500 | 10 | 38 40 | 1 8290 ± 0 1826 (−3 1) | 47 6 ± 3 5 (−6 2)
0 + 1,000 | 10 | 39 02 | 2 0970 ± 0 2450 (+11 1)^*^ | 53 7 ± 4 8 (+5 9)
200 + 250 | 10 | 37 98 | 1 8130 ± 0 2097 (−3 9) | 47 8 ± 5 4 (−5 8)
200 + 500 | 10 | 38 69 | 1 9250 ± 0 2290 (+2 0) | 49 7 ± 4 9 (−2 0)
200 + 1,000 | 10 | 38 22 | 1 9470 ± 0 1543 (+3 2) | 50 9 ± 3 7 (+0 5)
400 + 250 | 10 | 39 15^*^ | 1 9210 ± 0 1926 (+1 8) | 49 0 ± 4 0 (−3 3)
400 + 500 | 10 | 38 77 | 1 9240 ± 0 2408 (+2 0) | 49 6 ± 5 6 (−2 1)
400 + 1,000 | 10 | 38 10 | 1 9940 ± 0 2212 (+5 7) | 52 5 ± 5 5 (+3 5)

Dose^a^ | n^b^ | Reproductive Organ Weight^e^
Dose^a^ | n^b^ | Left Testis | Left Epididymis
0 + 0 | 10 | 0 1256 ± 0 0042^f^ | 0 0476 ± 0 0026
200 + 0 | 10 | 0 1272 ± 0 0062 | 0 0512 ± 0 0013
400 + 0 | 10 | 0 1148 ± 0 0065 | 0 0486 ± 0 0015
0 + 250 | 10 | 0 1270 ± 0 0037 | 0 0498 ± 0 0015
0 + 500 | 10 | 0 1173 ± 0 0040 | 0 0490 ± 0 0013
0 + 1,000 | 10 | 0 1227 ± 0 0060 | 0 0500 ± 0 0012
200 + 250 | 10 | 0 1181 ± 0 0071 | 0 0491 ± 0 0023
200 + 500 | 10 | 0 1266 ± 0 0059 | 0 0499 ± 0 0024
200 + 1,000 | 10 | 0 1221 ± 0 0070 | 0 0485 ± 0 0019
400 + 250 | 10 | 0 1205 ± 0 0028 | 0 0504 ± 0 0016
400 + 500 | 10 | 0 1225 ± 0 0052 | 0 0524 ± 0 0015
400 + 1,000 | 10 | 0 1190 ± 0 0065 | 0 0470 ± 0 0016

a AZT + clarithromycin in mg/kg per day

b n = number of values included in calculations, unless otherwise indicated

c Group mean body weight in grams

d Liver weights are presented as group mean ± standard deviation (% difference from control group, NA = not applicable) Absolute weights in grams, relative weights (organ-weight-to-body-weight ratios) are mg liver weight/g body weight

e Reproductive organ weights are presented in grams as group mean ± standard error

f n = 9

* P≤0 05 compared to 0 + 0 (control) group by the Student’s t-test

Female-A Mice

Dose^a^ | n^b^ | Body Weight^c^ | Liver Weight^d^
Dose^a^ | n^b^ | Body Weight^c^ | Absolute | Relative
0 + 0 | 18 | 36 87 | 2 457 ± 0 247 (NA) | 66 6 ± 5 3 (NA)
200 + 0 | 16 | 37 79 | 2 484 ± 0 299 (+1 1) | 65 6 ± 6 1 (−1 5)
400 + 0 | 15 | 36 43 | 2 223 ± 0 419 (−9 5)^*^ | 60 6 ± 7 2 (−9 0)^*^
0 + 250 | 16 | 37 46 | 2 592 ± 0 170 (+5 5) | 69 2 ± 4 0 (+3 9)
0 + 500 | 15 | 37 35 | 2 526 ± 0 199 (+2 8) | 67 6 ± 2 8 (+1 5)
0 + 1,000 | 12 | 37 26 | 2 593 ± 0 324 (+5 5) | 69 5 ± 6 3 (+4 4)
200 + 250 | 18 | 37 89 | 2 441 ± 0 329 (−0 7) | 64 3 ± 6 7 (−3 4)
200 + 500 | 16 | 38 51 | 2 464 ± 0 282 (+0 3) | 63 9 ± 5 3 (−4 1)
200 + 1,000 | 9 | 37 57 | 2 420 ± 0 439 (−1 5) | 64 1 ± 8 8 (−3 8)
400 + 250 | 13 | 33 75^*^ | 2 173 ± 0 547 (−11 6)^*^ | 65 7 ± 18 1 (−1 4)
400 + 500 | 4 | 34 75 | 1 753 ± 0 356 (−28 7)^*^ | 50 3 ± 2 8 (−24 5)^*^
400 + 1,000 | 2 | 35 65 | 2 385 ± 0 191 (−2 9) | 66 9 ± 5 2 (+0 4)

a AZT + clarithromycin in mg/kg per day

b n = number of values included in calculations Values exclude early deaths, dams designated as not pregnant, dams that delivered or began delivery prior to scheduled sacrifice, and dams that were sacrificed on an estimated day 14 or 18 of gestation

c Group mean body weight in grams

d Liver weights are presented as group mean ± standard deviation (% difference from control group, NA = not applicable) Absolute weights in grams, relative weights (organ-weight-to-body-weight ratios) are mg liver weight/g body weight

* P≤0 05 compared to 0 + 0 (control) group by the Student’s Mest