# References

Amin, N.M. (1989). Zidovudine for treating AIDS. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine. Amer. J. Med. 85, 186–188.3044084
Barnes, P.F., Bloch, A.B., Davidson, P.T., and Snider, D.E. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Eng. J. Med.. 324, 1644–1650.
Benson, W.M., Stefko, P.L., and Roe, M.D. (1952). Pharmacologic and toxicologic observations on hydrazine derivatives of isonicotinic acid (Rimifon, Marsilid). Am. Rev. Tuberculosis 65, 376–391.
Bick, R.L., Ed. (1993). Hematology — Clinical and Laboratory Practice, pp. 185–201. Mosby Press, St. Louis.
Black, M., Mitchell, J.R., Zimmerman, H.J., Ishak, K.G., and Epler, G.R. (1975). Isoniazid-associated hepatitis in 114 patients. Gastroenterology 69, 289–302.1150039
Blakemore, W.F. (1986). Isoniazid. Neurotoxicology 1706, 476–489.
Blanchard, J.S. (1996). Molecular mechanisms of drug resistance in Mycobacterium tuberculosis. Annu. Rev. Biochem. 65, 215–239.8811179
Bucher, H.C., Griffith, L.E., Guyatt, G.H., Sudre, P., Naef, M., Sendi, P., and Battegay, M. (1999). Isoniazid prophylaxis for tuberculosis in HIV infection: a meta-analysis of randomized controlled trials. AIDS 13, 501–507.10197379
Centers for Disease Control and Prevention (CDC) (1987). Diagnosis and management of mycobacterial infection and disease in persons with human immunodeficiency virus infection. Ann. Intern. Med. 106, 254–256.3800186
Centers for Disease Control and Prevention (CDC) (1998). Prevention and treatment of tuberculosis among patients infected with human immunodeficiency virus: principles of therapy and revised recommendations. MMWR 47(RR20), 1–51.
Chow, R.F., Sutton, P.A., and Hamburger, A.W. (1991). Sensitivity of erythroid progenitor colonies to erythropoietin in azidothymidine treated immunodeficient mice. Brit. J. Haematol. 77, 139–144.2004015
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Cretton, E.M., Xie, M.Y., Bevan, R.J., Goudgaon, N.M., Schinazi, R.F., and Sommadossi, J.P. (1991). Catabolism of 3′-azido-3′-deoxythymidine in hepatocytes and liver microsomes, with evidence of formation of 3′-amino-3′-deoxythymidine, a highly toxic catabolite for human bone marrow cells. Mol. Pharmacol. 39(2), 258–266.1996084
Dixon, W.J., and Massey, F.J., Jr. (1951). Introduction to Statistical Analysis, 1st ed., pp. 145–147. McGraw-Hill Book Company, New York.
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, W. (1955). A multiple comparison procedure for comparing several treatments with a control. JASA 50, 1095–1121.
Fahrmeir, L., and Tutz, G. (1994). Multivariate Statistical Modeling Based on Generalized Linear Models, p. 73. Springer-Verlag, New York.
Freireich, E.J., Gehan, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Can. Chem. Rep. 50, 219–244.
Gogu, S.R., Beckman, B.S., Wilson, R.B., and Agrawal, K.C. (1995). Inhibitory effects of zidovudine in erythroid progenitor cells: reversal with a combination of erythropoietin and interleukin-3. Biochem. Pharm. 50, 413–419.7646543
Goldschmidt, R.H., and Dong, B.J. (1992). Current Report - HIV. Treatment of AIDS and HIV-related conditions: 1992. J. American Board Family Pract. 5, 335–350.
Goodman and Gilman’s The Pharmacological Basis of Therapeutics (2001). 10th ed. (A.G. Gilman, J.G. Hardman, and L.E. Limbird, Eds.), pp. 1273–1276. McGraw-Hill, New York.
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii Pneumonia and mucosal candidiasis in previously healthy homosexual men: evidence of a new acquired cellular immunodeficiency. New Eng. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. American Optometric Assoc. 63, 35–42.
Harper, K.H., and Worden, A.N. (1966). Comparative toxicity of isonicotinic acid hydrazide and its methanosulfonate derivative. Toxicol. Appl. Pharmacol. 8, 325–333.5956883
Humma, L.M. (1996). Prevention and treatment of drug-resistant tuberculosis. Am. J. Health – Syst. Pharm. 53, 2291–2298.8893067
Jacobson, M.A. (1988). Mycobacterial diseases: Tuberculosis and mycobacterium avium complex. In: Medical Management of AIDS (M.A. Sande, Ed.), pp. 235–246. W.B. Saunders, Philadelphia.
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18, 5–13.2464649
Jonkheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Maddrey, W.C., and Boitnott, J.K. (1973). Isoniazid hepatitis. Ann. Intern. Med. 79, 1–12.4721174
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biologic and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrobial Agents Chemother. 34, 637–641.
Maronpot, R.R., Boorman, G.A., and Gaul, B.W. (1999). Pathology of the Mouse, p. 339. Cache River Press, Vienna, FL.
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Vande Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: initial manifestations of cellular immune dysfunction. New Eng. J. Med. 305, 1431–1438.6975437
Mate, N.B., Maru, G.B., and Bhide, S.V. (1981). Studies on tumorigenicity and metabolism of isoniazid in mice and rats. Ind. J. Exp. Biol. 19, 1037–1039.
McCullagh, P., and Nelder, J.A. (1989). Generalized Linear Models, 2nd ed., pp. 35–36. Chapman and Hall, London.
Menon, M.M., and Bhide, S.V. (1980). Transplacental, biological, and metabolic effects of isoniazid (INH) in Swiss mice. Ind. J. Exp. Biol. 18, 1104–1106.
Menon, M.M., and Bhide, S.V. (1983). Perinatal carcinogenicity of isoniazid (INH) in Swiss mice. J. Cancer Res. Clin. Oncol. 105, 258–261.6853587
Mitchell, J.R., Zimmerman, H.J., Ishak, K.G., Thorgeirsson, U.P., Timbrell, J.A., Snodgrass, W.R., and Nelson, S.D. (1976). Isoniazid liver injury: Clinical spectrum, pathology, and probable pathogenesis. Ann. Intern. Med. 84, 181–192.766682
Murray, J.F. (1998). Tuberculosis and HIV infection: A global perspective. Respiration 65, 335–342.9782213
National Institute of Environmental Health Sciences (NIEHS) (1999). Reproductive, Developmental, and General Toxicity Study of 3′-Azido-3′-deoxythymidine (AZT) and Isoniazid Combinations Administered by Gavage to Swiss (CD-1^®^) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 3 (NIH Publication 99-3941). U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, NC.
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/a-interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, Research Triangle Park, N.C.
Nolan, C.M. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Amer. J. Infect. Control 20, 30–34.1554145
Peretti, E., Karlagnanis, G., and Lauterburg, B.H. (1987). Acetylation of acetylhydrazine, the toxic metabolite of isoniazid in humans. Inhibition by concomitant administration of isoniazid. J. Pharmacol. Exp. Ther. 243, 686–689.3681700
Physician’s Desk Reference (PDR) (1999). 53rd ed., pp. 1172–1174 and 1202–1207. Medical Economics Data Production Co., Montvale, NJ.
Pozniak, A.L., Miller, R., and Ormerod, L.P. (1999). The treatment of tuberculosis in HIV-infected persons. AIDS 13, 435–445.10197371
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infect. Dis. Clin. North Am. 2, 397–497.2462584
Richman, D.D., Fischl, M.A., Grieco, M.H., Gottlieb, M.S., Volberding, P.A., Laskin, O.L., Leedom, J.M., Groopman, J.E., Mildvan, D., Hirsch, M.S., Jackson, G.G., Durack, D.T., Phil, D., Nusinoff-Lehrman, S., and the AZT Collaborative Working Group (1987). The toxicity of azidothymidine (AZT) in the treatment of patients with AIDS and AIDS-related complex. New Eng. J. Med. 4, 192–197.
Rubin, B., and Burke, J.C. (1953). Absorption, distribution, and excretion of isoniazid (Nydrazid) in the dog. Proc. Soc. Exp. Biol. Med. 107, 219–224.
Rubin, B., Hassert, G.L., Thomas, B.G.H., and Burke, J.C. (1952). Pharmacology of isonicotinic acid hydrazide (Nydrazid). Am. Rev. Respir. Dis. 65, 392–402.
Sheehan, D.C., and Hrapchak, B.B. (1980). Theory and practice of histotechnology, 2nd ed., p. 217. Batelle Press, Columbus, OH.
Shirley, E. (1977). A non-parametric equivalent of Williams’ test for contrasting increasing dose levels of a treatment. Biometrics 33, 386–389.884197
Siegle, F.P., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Ashberg, B.R., Parham, D.M., Siegel, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. New Eng. J. Med. 305, 1439–1444.6272110
Snower, D.P., and Weil, S.C., (1993). Changing etiology of macrocytosis. Am. J. Clin. Pathol. 99, 57–60.8422018
Stevens, J. (1986). Applied Multivariate Statistics for the Social Sciences, Chapter 3. L. Erlbaum Associates, Hillsdale, NJ.
Stuart, R.L., and Grayson, M.L. (1999). A review of isoniazid-related hepatotoxicity during chemoprophylaxis. Aust. N.Z. J. Med. 29, 362–369.10868500
Tannen, R.H., and Weber, W.W. (1979). Rodent models of the human isoniazid-acetylator polymorphism. Drug Metab. Dispos. 7, 274–279.40765
Thompson, M.B., Dunnick, J.K., Sutphin, M.E., Giles, H.D., Irwin, R.D., and Prejean, J.D. (1991). Hematologic toxicity of AZT and ddC administered as single agents and in combination to rats and mice. Fund. Appl. Tox. 17, 159–176.
Timbrell, J.A. (1979). The role of metabolism in the hepatotoxicity of isoniazid and iproniazid. Drug Metab. Rev. 10, 125–147.393481
Timbrell, J.A. (1981). Isoniazid metabolism in relation to hepatotoxicity. In: Drug Reactions in the Liver (M. Davis, J.M. Tredger, and R. Williams, Eds.), pp. 190–196. Pitman Medical, London.
Timbrell, J.A., Mitchell, J.R., Snodgrass, W.R., and Nelson, S.D. (1980). Isoniazid hepatotoxicity: The relationship between covalent binding and metabolism in vivo. J. Pharmacol. Exp. Ther. 213, 364–369.6767840
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F_1_ mice. Drug Metab. Dispos. 21, 189–193.8095218
Toltzis, P., Celeste, M.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Vasudeva, R., and Woods, B. (1997). Isoniazid-related hepatitis. Dig. Dis. 15, 357–367.9439900
Vince, R., Hua, M., Brownell, J., Daluge, S., Fangchem, L., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against Human Immunodeficiency Virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics. 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics. 28, 519–531.5037867