# Peer Review

The draft report on the 13-week toxicity study of 3′-azido-3′-deoxythymidine (AZT) and isoniazid combinations was evaluated by the following reviewers. These reviewers served as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of the study are appropriate and ensure that this 13-week toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- Curtis D. Klaassen, Ph.D.
  Department of Pharmacology and Toxicology
  University of Kansas Medical Center
  Kansas City, KS
- David E. Malarkey, D.V.M, Ph.D.
  College of Veterinary Medicine
  North Carolina State University
  Raleigh, NC