# Discussion and Conclusions

A 13-week toxicity study was conducted in which male and female B6C3F_1_ mice were treated with 3′-azido-3′-deoxythymidine (AZT) alone (100, 200, or 400 mg/kg per day), isoniazid alone (50, 100, or 150 mg/kg/day), or combinations of AZT and isoniazid. The test articles were administered by oral gavage for approximately 13 weeks.

Measurable evidence of hematopoietic toxicity occurred in mice of both sexes treated with AZT alone, and the most significant alteration consisted of a mild anemia. The anemia was accompanied by elevations in MCV and MCH values and, therefore, could be classified as macrocytic. The mild macrocytic anemia was accompanied microscopically by splenic hematopoiesis and bone marrow depression. Elevated reticulocyte counts also occurred in mice of both sexes treated with AZT alone; however, the extent of the reticulocytosis was not as great as the extent of the macrocytosis. The mild macrocytic anemia that occurred with AZT treatment is compatible with the anemia previously reported in mice (Thompson et al., 1991). Macrocytic anemia is a common observation in humans treated with AZT (Snower and Weil, 1993; Richman et al., 1987). The exact mechanism of the erythrocyte macrocytosis is unclear but it likely reflects inhibition of DNA synthesis in erythroid precursors. AZT is directly toxic to erythroid blast forming units (BFU-E) and erythroid colony forming units (CFU-E) in vitro at high concentrations and is antiproliferative in CFU-E at lower concentrations (Gogu et al., 1995). In in vivo studies, AZT has been shown to increase splenic and bone marrow BFU-E in mice and to increase the sensitivity of both splenic and bone marrow BFU-E to erythropoietin (Chow et al., 1991); both effects occur in the absence of an appreciable regenerative response (reticulocytosis), suggesting a maturation block in the erythroid series due to a block in terminal differentiation. AZT has since been shown to down-regulate the erythropoietin receptor in CFU-E and inhibit erythropoietin receptor-mediated signal transduction (Gogu et al., 1995). These mechanisms could inhibit CFU-E proliferation and possibly affect erythropoietin-regulated maturation (Bick, 1993). The disproportionate reticulocyte response, when compared to the extent of the macrocytosis observed in this study, suggests that the anemia caused by AZT administration is compatible with depression of erythroid precursors due to impaired DNA synthesis. Other alterations associated with AZT therapy in mice consisted of a slight increase in platelet counts, increased pigmentation of the skin, and a slight decline in epididymal sperm motility.

Administration of isoniazid alone resulted in slight hepatotoxicity manifested by minimal to mild paracentral and midzonal hepatocellular hypertrophy and cytoplasmic pigment deposition in the liver of male mice. In human patients, isoniazid-related hepatotoxicity ranges from asymptomatic elevations in serum enzymes indicative of liver toxicity to fulminant hepatic failure and death (Vasudeva and Woods, 1997). Microscopic findings reported in the liver of human patients with isoniazid toxicity consist of acute hepatocellular injury with ballooning degeneration, sinusoidal acidophilic bodies, focal necrosis, patchy hepatitis with inflammation, multilobular necrosis, and cirrhosis (Maddrey and Boitnott, 1973; Black et al., 1975; Mitchell et al., 1976). The manifestations of liver toxicity in mice in this study, even at three times the human therapeutic dose (adjusted for body surface area), are different from those described in human patients as necrosis and inflammation did not occur and there were no increases in serum enzymes indicative of liver toxicity. The absence of serum enzyme alterations with isoniazid treatment in this study is consistent with the results from a previous study conducted in Swiss (CD-1^®^) mice treated with the same dose levels of isoniazid for up to 30 days (NIEHS, 1999).

Administration of AZT in combination with isoniazid to male and female B6C3F_1_ mice resulted in hematopoietic toxicity of greater severity than that resulting from the administration of AZT alone. Bone marrow suppression and severe anemia resulted in significant mortality in female mice treated with the highest combinations of AZT and isoniazid. The higher mortality rate in the female clinical pathology groups, as compared to core study animals, likely reflects the underlying treatment-related anemia in combination with the repeated blood sampling procedure. Since isoniazid administration resulted in alterations in hepatocyte morphology, the exacerbation of hematopoietic toxicity subsequent to combination therapy may be the result of isoniazid interfering with the metabolism of AZT. The liver is considered the major site for AZT catabolism and some AZT catabolites are five-to sevenfold more toxic than AZT (Cretton et al., 1991). Exacerbation of hematopoietic toxicity with the higher combinations of AZT and isoniazid in this study is consistent with the enhanced hematological toxicity that occurred in a previous study (NIEHS, 1999) conducted in Swiss (CD-1^®^) mice treated with the same doses for up to 30 days. Other less dramatic alterations occurring in mice treated with combination therapy consisted of diminished body weight, reticulocytopenia followed by reticulocytosis, thrombocytosis, leukopenia, neutropenia, lymphopenia, and a slight increase in the duration of estrus.

## Conclusions

Administration of AZT alone to B6C3F_1_ mice resulted in dose- and duration-of-treatment-related hematopoietic toxicity manifested primarily by a mild macrocytic anemia. Administration of isoniazid alone did not cause hematopoietic toxicity but caused minimal to mild hepatotoxicity manifested by hepatocellular hypertrophy and pigment deposition in the liver. However, isoniazid, when administered in combination with AZT, increased the hematopoietic toxicity induced by AZT, resulting in treatment-related mortality. Results of this study indicate that toxicological effects of combination therapy can be considerably more severe than the toxicity of individual therapies and isoniazid may have potentiated the hematopoietic toxicity of AZT.