# Results

## Survival and Clinical Findings

In the core study, a total of six early deaths or moribund sacrifices occurred prior to terminal sacrifice. A single male mouse treated with 100 mg/kg 3′-azido-3′-deoxythymidine (AZT) alone died on day 67 (week 10). All five of the early deaths in female mice occurred on day 43 (week 7). One female mouse treated with 400 mg/kg AZT + 50 mg/kg isoniazid and three females in the group treated with 400 mg/kg AZT + 150 mg/kg isoniazid were sacrificed due to a moribund condition. One additional female mouse treated with 400 mg/kg AZT + 150 mg/kg isoniazid was found dead. Prominent clinical findings occurring prior to these deaths included paleness, hypothermia, lethargy, increased respiration rate, and hunched posture.

In the clinical pathology groups, a total of nine early deaths or moribund sacrifices occurred, and all were female mice treated with 200 or 400 mg/kg AZT + 150 mg/kg isoniazid. One female mouse in the 200 mg/kg AZT + 150 mg/kg isoniazid group was sacrificed moribund on day 39 (week 6). Seven female mice treated with 400 mg/kg AZT + 150 mg/kg isoniazid were sacrificed moribund or found dead on days 31 and 32 (week 5), and one additional mouse in this group was found dead on day 39 (week 6). The majority of these deaths occurredshortly after the interim clinical pathology evaluation on day 30 and were attributed to the blood sampling procedure in combination with an underlying anemia.

Other clinical signs related to treatment consisted of darkened skin on the muzzle, tail, and feet, and feet appearing white. Darkened skin occurred in mice treated with the higher doses of AZT alone or in combination with isoniazid from week 7 until the end of the study. The darkened skin was believed to reflect increased pigmentation subsequent to the administration of AZT and was consistent with clinical findings reported previously (NTP, 1999). The clinical finding of feet appearing white occurred in groups treated with the highest combinations of AZT and isoniazid and was considered to be a reflection of anemia from treatment and/or the blood sampling procedure.

## Body and Organ Weights

Administration of AZT (100, 200, or 400 mg/kg) alone, isoniazid (50, 100, or 150 mg/kg) alone, and combinations of AZT and isoniazid to male mice did not result in significant (P≤0.05) declines in body weights (Figure 1; Table A1). For the male group treated with 100 mg/kg AZT + 50 mg/kg isoniazid, the mean terminal body weight was approximately 12% (38.86 grams; P≤0.05) higher than the mean (34.62 grams) in the controls (Table A2). The increased terminal body weights in this group were not considered to be biologically significant as a dose-related pattern did not occur.

Although not statistically significant (P≤0.05), administration of 100, 200, or 400 mg/kg AZT to female mice resulted in slight declines in terminal body weights (Table A2). Respective mean terminal body weights were approximately 3% (27.39 grams), 4% (27.02 grams), and 3% (27.26 grams) lower than the mean (28.18 grams) in the control group. Administration of 50 or 100 mg/kg isoniazid alone to female mice did not result in diminished body weights (Figure 2; Table A1). Although not statistically significant (P≤0.05), the mean terminal body weight in the group treated with 150 mg/kg isoniazid alone was approximately 5% (26.78 grams) lower than the mean (28.18 grams) in the controls (Table A2). Administration of AZT and isoniazid combinations to female mice did not result in statistically significant (P≤0.05) alterations in body weight (Figure 2; Table A1); however, slight declines did occur in the female groups receiving AZT + 150 mg/kg isoniazid. Respective mean terminal body weights for female groups treated with 100 or 200 mg/kg AZT + 150 mg/kg isoniazid (Table A2) were approximately 5% (26.87 grams) and 8% (25.85 grams) lower than the mean (28.18 grams) in the controls. For the female group treated with 400 mg/kg AZT + 150 mg/kg isoniazid, a marked decline in mean body weight occurred on day 39 (Figure 2; Table A1). After this date, significant mortality (4 deaths during week 7) occurred in this group and the mean terminal body weight of the survivors was similar to that of the control group.

With the exception of the male group treated with 200 mg/kg AZT + 50 mg/kg isoniazid and the female group treated with 100 mg/kg isoniazid alone, mean thymic weights in all treatment groups were slightly lower than mean thymic weights in male and female control groups (Table A2). The slight declines in absolute thymic weights were significant (P≤0.05) in the male groups treated with 200 mg/kg AZT alone, 200 mg/kg AZT + 50 mg/kg isoniazid, or 200 mg/kg AZT + 100 mg/kg isoniazid and in female groups treated with 100 mg/kg AZT alone, 400 mg/kg AZT + 50 mg/kg isoniazid, or 400 mg/kg AZT + 150 mg/kg isoniazid. Relative thymic weights (thymus weight/body weight ratio) were lower in mice of both sexes when compared to controls (Table A2). Declines in relative thymic weights were significant (P≤0.05) in male groups treated with 200 mg/kg AZT alone, 50 mg/kg isoniazid alone, 100 or 400 mg/kg AZT + 50 mg/kg isoniazid, 200 mg/kg AZT + 100 mg/kg isoniazid, or 100 or 400 mg/kg AZT + 150 mg/kg isoniazid. For the female mice, the declines in relative thymic weights were significant (P≤0.05) in groups treated with 200 or 400 mg/kg AZT in combination with 50 mg/kg isoniazid. The reductions in absolute and relative thymic weights may be a reflection of stress as opposed to a direct toxic effect. Minor statistically significant (P≤0.05) alterations in other organ weight or organ-to-body-weight ratios (liver, kidney, heart, lungs, and testicle) occurred in a random or sporadic distribution (Table A2) and, as such, were not considered to be treatment related.

FIGURE 1 Mean Body Weights of Male (Core) Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

FIGURE 2 Mean Body Weights of Female (Core) Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

* Moribund mice lowered the mean body weight for the group.

## Clinical Pathology

### Hematology

#### AZT Alone

Administration of 100, 200, or 400 mg AZT per kg body weight alone to male and female mice produced dose- and duration-of-treatment-related anemia, thrombocytosis, and a transient reticulocytopenia followed by reticulocytosis. In general, the hematological alterations were slightly more prevalent in female mice than in males. The anemia was accompanied by elevations in mean corpuscular volume (MCV) and mean corpuscular hemoglobin (MCH) values and, as such, could be classified as macrocytic.

On day 4, marginal declines in red blood cell (RBC) counts occurred only in female mice. Respective mean RBC counts (Figure 4; Table B1) for female groups treated with 100, 200, or 400 mg/kg AZT were approximately 7% (9.10 × 10^6^/_L; P≤0.01), 5% (9.25 × 10^6^/_L; P≤0.05), and 6% (9.23 × 10^6^/_L; P≤0.05) lower than the mean RBC count (9.77 × 10^6^/_L) in the control group. On day 30, dose-related declines in RBC counts occurred in mice of both sexes. Respective mean RBC counts on day 30 (Figure 3; Table B1) for male mice treated with 100, 200, or 400 mg/kg AZT were approximately 13% (8.62 × 10^6^/_L; P≤0.01), 14% (8.50 × 10^6^/_L; P≤0.01), and 21% (7.80 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.91 × 10^6^/_L) in the male control group. Respective mean RBC counts on day 30 (Figure 4; Table B1) for the female groups treated with the same doses were approximately 16% (7.96 × 10^6^/_L; P≤0.01), 20% (7.63 × 10^6^/_L; P≤0.01), and 25% (7.15 × 10^6^/_L; P≤0.01) lower than the mean (9.49 × 10^6^/_L) in the female control group. Similar dose-related declines in RBC counts occurred in male and female mice on day 60. Respective mean RBC counts on day 60 for male mice (Figure 3; Table B1) treated with 100, 200, or 400 mg/kg AZT were approximately 16% (8.63 × 10^6^/_L; P≤0.01), 21% (8.10 × 10^6^/_L; P≤0.01), and 27% (7.46 × 10^6^/_L) lower than the mean (10.27 × 10^6^/_L) for the male controls. Female groups treated identically (Figure 4; Table B1) had respective mean RBC counts approximately 13% (8.26 × 10^6^/_L; P≤0.01), 21% (7.45 × 10^6^/_L; P≤0.01), and 24% (7.20 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.48 × 10^6^/_L) for the female controls. An anemia of similar severity was present in male and female mice at the time of terminal sacrifice on days 92 to 95. For the male mice treated with 100, 200, or 400 mg/kg AZT, respective mean RBC counts (Figure 3; Table B1) were approximately 13% (8.54 × 10^6^/_L; P≤0.01), 20% (7.91 × 10^6^/_L; P≤0.01), and 27% (7.18 × 10^6^/_L; P≤0.01) lower than the mean (9.83 × 10^6^/_L) in the control group. For the female mice treated with the same AZT doses, respective mean RBC counts (Figure 4; Table B1) were approximately 20% (7.73 × 10^6^/_L; P≤0.01), 24% (7.35 × 10^6^/_L; P≤0.01), and 29% (6.84 × 10^6^/_L; P≤0.01) lower than the mean (9.63 × 10^6^/_L) in the control group. In general for mice of both sexes, declines in hemoglobin (HGB) and hematocrit (HCT) values (Table B1) accompanied the dose-related declines in RBC counts at all of the bleeding intervals (days 4, 30, 60, and 92 to 95). However, the declines in HGB and HCT values were not as marked as the RBC counts because of macrocytic erythrocytes.

Elevations in MCV and MCH values accompanied the dose-related declines in RBC counts in male and female mice on days 30, 60, and 92 to 95 (Table B1). On day 30, respective mean MCV values in male mice (Figure 5) treated with 100, 200, or 400 mg/kg AZT were approximately 8% (52.2 fL; P≤0.01), 12% (54.2 fL; P≤0.01), and 16% (56.5 fL; P≤0.01) higher than the mean MCV value (48.5 fL) in the control group. Respective mean MCH values (Table B1) for the same groups were approximately 9% (17.7 pg; P≤0.01), 10% (17.9 pg; P≤0.01), and 14% (18.6 pg; P≤0.01) higher than the mean (16.3 pg) for the controls. For the female mice treated with 100, 200, or 400 mg/kg AZT alone, respective mean MCV values on day 30 (Figure 6) were approximately 11% (54.9 fL; P≤0.01), 15% (56.7 fL; P≤0.01), and 18% (58.5 fL; P≤0.01) higher than the mean MCV value (49.5 fL) in the control group. Corresponding MCH values (Table B1) were approximately 10% (18.2 pg; P≤0.01), 12% (18.5 pg; P≤0.01), and 15% (18.9 pg; P≤0.01) higher than the mean MCH value (16.5 pg) in the control group. The severity of the macrocytosis was greater on day 60 in mice of both sexes (Table B1). Respective mean MCV values on day 60 for male mice (Figure 5) treated with 100, 200, or 400 mg/kg AZT were approximately 11% (53.4 fL; P≤0.01), 16% (56.1 fL; P≤0.01), and 21% (58.5 fL; P≤0.01) higher than the mean (48.3 fL) for the controls. Corresponding mean MCH values were approximately 9% (17.7 pg; P≤0.01), 14% (18.4 pg; P≤0.01), and 18% (19.1 pg; P≤0.01) higher than the mean MCH value (16.2 pg) for the controls. For the female groups treated identically, respective mean MCV values (Figure 6) were approximately 15% (54.4 fL; P≤0.01), 20% (56.8 fL; P≤0.01), and 25% (59.4 fL; P≤0.01) higher than the mean MCV value (47.5 fL) in the female control group. Corresponding mean MCH values for the female groups were approximately 13% (18.1 pg; P≤0.01), 18% (18.8 pg; P≤0.01), and 22% (19.5 pg; P≤0.01) higher than the mean (16.0 pg) for the controls. A dose-related macrocytosis also occurred in mice of both sexes at terminal sacrifice (days 92 to 95). Respective mean MCV values on days 92 to 95 for male mice (Figure 5) treated with 100, 200, or 400 mg/kg AZT were approximately 13% (52.7 fL; P≤0.01), 18% (55.1 fL; P≤0.01), and 25% (58.4 fL; P≤0.01) higher than the mean MCV value (46.7 fL) for the male control group. Corresponding mean MCH values were approximately 11% (17.5 pg; P≤0.01), 16% (18.3 pg; P≤0.01), and 20% (19.0 pg; P≤0.01) higher than the mean MCH value (15.8 pg) for the controls. For the female groups treated identically, respective mean MCV values were approximately 17% (54.6 fL; P≤0.01), 21% (56.4 fL; P≤0.01), and 26% (58.9 fL; P≤0.01) higher than the mean MCV value (46.8 fL) in the female control group. Corresponding mean MCH values for the female groups were approximately 15% (18.3 pg; P≤0.01), 17% (18.6 pg; P≤0.01), and 21% (19.3 pg; P≤0.01) higher than the mean MCH value (15.9 pg) for the controls. Marginal statistically significant declines (P≤0.01 to P≤0.05) in mean corpuscular hemoglobin concentration (MCHC) occurring in the higher dose male groups (days 30 and 92 to 95) and female groups (days 60 and 92 to 95) were not considered to be biologically significant (Table B1).

Administration of AZT alone to male and female mice resulted in an initial reticulocytopenia (day 4) followed by reticulocytosis at the day 30, 60, and 92 to 95 bleeding intervals (Table B1). Respective mean reticulocytic counts on day 4 in male mice (Figure 7) treated with 100, 200, or 400 mg/kg AZT alone were approximately 28% (2.8 × 10^5^/_L; P≤0.01), 36% (2.5 × 10^5^/_L; P≤0.01), and 44% (2.2 × 10^5^/_L) lower than the mean reticulocyte count (3.9 × 10^5^/_L) in the control group. For female mice treated with the same AZT doses (Figure 8), reticulocyte counts on day 4 were approximately 44% (1.5 × 10^5^/_L; P≤0.01), 52% (1.3 × 10^5^/_L; P≤0.01), and 52% (1.3 × 10^5^/_L; P≤0.01) lower than the mean (2.7 × 10^5^/_L) in the female control group. Reticulocyte counts rebounded in mice of both sexes by day 30. Respective mean reticulocyte counts on day 30 for male mice treated with 100, 200, or 400 mg/kg AZT alone (Figure 7) were approximately 1.1 times (3.4 × 10^5^/_L), 1.2 times (3.6 × 10^5^/_L; P≤0.05), and 1.4 times (4.1 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.0 × 10^5^/_L) in the controls. For the female groups (Figure 8) treated identically, respective mean reticulocyte counts were approximately 1.2 times (3.5 × 10^5^/_L), 1.5 times (4.6 × 10^5^/_L; P≤0.05), and 1.6 times (4.8 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.0 × 10^5^/_L) in the control group. A dose-related increase in reticulocytes was observed in mice of both sexes on day 60. Respective mean reticulocyte counts on day 60 in male groups (Figure 7) treated with 100, 200, or 400 mg/kg AZT alone were approximately 1.1 times (3.5 × 10^5^/_L; P≤0.05), 1.3 times (3.9 × 10^5^/_L; P≤0.01), and 1.5 times (4.6 × 10^5^/_L; P≤0.01) the mean (3.1 × 10^5^/_L) in the controls. For the female groups (Figure 8) treated identically, respective mean reticulocyte counts on day 60 were approximately 1.2 times (4.0 × 10^5^/_L), 1.2 times (3.8 × 10^5^/_L), and 1.4 times (4.6 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.3 × 10^5^/_L) in the control group. A dose-related reticulocytosis also occurred in mice of both sexes at terminal sacrifice (days 92 to 95). On days 92 to 95, respective mean reticulocyte counts in the male groups treated with 100, 200, or 400 mg/kg AZT alone (Figure 7) were approximately 1.1 times (4.0 × 10^5^/_L), 1.3 times (4.8 × 10^5^/_L; P≤0.01), and 1.5 times (5.4 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.7 × 10^5^/_L) in the male control group. For the female groups treated identically (Figure 8), respective mean reticulocyte counts were approximately 1.2 times (3.9 × 10^5^/_L), 1.5 times (4.9 × 10^5^/_L; P≤0.05), and 1.8 times (6.2 × 10^5^/_L; P≤0.01) the mean (3.3 × 10^5^/_L) in the female control group.

In general, for the male and female groups treated with the highest doses of AZT, significant (P≤0.01) increases in reticulocyte counts correlated with significant (P≤0.01) increases in MCV values on days 30, 60, and 92 to 95. However, for the male (days 30 and 92 to 95) and female groups (days 30, 60, and 92 to 95) treated with 100 mg/kg AZT alone, significant (P≤0.01) increases in MCV values were not accompanied by elevated reticulocyte counts (P>0.05), suggesting that the macrocytosis was not proportional to the reticulocytosis.

Administration of AZT alone to male and female mice resulted in treatment-related increases in platelet counts (Table B1). For the male mice in the 400 mg/kg group, the mean platelet count (Figure 9) on days 92 to 95 was approximately 1.3 times (1,568 × 10^3^/_L; P≤0.01) the mean (1,222 × 10^3^/_L) in the control group. For the female mice on day 60, the mean platelet count (Figure 10) in the 400 mg/kg AZT group was approximately 1.3 times (1,461 × 10^3^/_L; P≤0.01) the mean (1,158 × 10^3^/_L) in the control group. On days 92 to 95, the mean platelet count in the high-dose female group (Figure 10) was approximately 1.3 times (1,517 × 10^3^/_L; P≤0.01) the mean platelet count (1,214 × 10^3^/_L) in the control group. Although not statistically significant when compared to control groups, platelet counts were also elevated in the high-dose male and female groups on day 30 and in the high-dose male group on day 60.

With the exception of the 400 mg/kg female group on day 30, significant (P≤0.05) declines in white blood cell (WBC) counts did not occur with AZT therapy alone (Table B1). The mean WBC count on day 30 in the high-dose female group was approximately 23% (6.09 × 10^3^/_L; P≤0.05) lower than the mean WBC count (7.91 × 10^3^/_L) in the controls. Evaluation of the corresponding differential data (Table B1) revealed slight declines in all types of the WBC. The significant decline (P≤0.05) in the monocyte counts was not believed to be biologically significant because of the low numbers of this cell type normally present in the differential. No other statistically significant (P≤0.05) alterations occurred in the differential data.

##### Isoniazid Alone

Administration of 50, 100, or 150 mg isoniazid/kg body weight alone to male and female mice did not result in consistent biologically significant hematological alterations (Table B1).

On day 4, a marginal decline in RBC counts occurred in the high-dose female group. The mean RBC count on day 4 in the female group treated with 150 mg/kg isoniazid (Figure 4) was approximately 6% (9.16 × 10^6^/_L; P≤0.01) lower than the mean (9.77 × 10^6^/_L) in the control group. This slight decline in the erythrocyte count was not believed to be biologically significant as no other alterations occurred in any of the other erythrocyte parameters evaluated in female mice on days 30, 60, or 92 to 95.

At the day 60 bleeding interval, minor declines in HGB and HCT values occurred in male groups treated with 100 or 150 mg/kg isoniazid alone (Table B1). Respective mean HGB values for the 100 and 150 mg/kg dose groups were approximately 5% (15.7 g/dL; P≤0.05) and 5% (15.7 g/dL; P≤0.01) lower than the mean (16.6 g/dL) for the control group. HCT values paralleled the HGB values. These minor declines were not believed to be biologically significant as RBC counts were within a normal range and significant (P≤0.05) alterations in RBC, HGB, or HCT values did not occur in male mice at terminal sacrifice.

On days 92 to 95, minor alterations in MCH and reticulocyte values occurred in the male group treated with 150 mg/kg isoniazid alone (Table B1). The mean MCH value was approximately 4% (15.2 pg; P≤0.05) lower than the mean (15.8 pg) for the control group, and the mean reticulocyte count was approximately 1.1 times (4.2 × 10^5^/_L; P≤0.05) the mean (3.7 × 10^5^/_L) for the control group. These statistically significant alterations in MCH and reticulocyte values were not believed to be biologically significant as anemia did not occur and there were no biologically significant alterations in any of the other hematology parameters evaluated.

##### AZT and Isoniazid Combinations

Administration of 100, 200, or 400 mg AZT/kg body weight in combination with 50, 100, or 150 mg isoniazid/kg body weight resulted in some hematological alterations of greater severity than those detected subsequent to the administration of AZT alone. In general, the macrocytic anemia, thrombocytosis, reticulocytopenia, and reticulocytosis that occurred subsequent to combination therapy were more prevalent in female mice than in males and were usually most evident in groups treated with 100, 200, or 400 mg/kg AZT in combination with 150 mg/kg isoniazid.

Significant declines in RBC counts occurred in mice of both sexes on day 4 (Table B1). The mean RBC count on day 4 in the male group treated with 400 mg/kg AZT + 150 mg/kg isoniazid (Figure 3) was approximately 8% (8.32 × 10^6^/_L; P≤0.01) lower than the mean (9.00 × 10^6^/_L) for the controls. On day 4, respective mean RBC counts (Figure 4) in female mice treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 7% (9.09 × 10^6^/_L; P≤0.01), 6% (9.17 × 10^6^/_L; P≤0.01), and 9% (8.89 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.77 × 10^6^/_L) for the female controls. The anemia was considerably more severe in both sexes on day 30 (Table B1). Respective mean RBC counts on day 30 in male mice (Figure 3) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 15% (8.44 × 10^6^/_L; P≤0.01), 20% (7.89 × 10^6^/_L; P≤0.01), and 29% (7.02 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.91 × 10^6^/_L) for the control group. For the female groups treated identically, mean RBC counts (Figure 4) were approximately 19% (7.71 × 10^6^/_L; P≤0.01), 38% (5.86 × 10^6^/_L; P≤0.01), and 77% (2.17 × 10^6^/_L; P≤0.01) lower than the mean (9.49 × 10^6^/_L) in the controls. The majority of the female mice in the high-dose combination group had severe anemia and died after the bleeding procedure on day 30. Anemia was also prominent in mice of both sexes on day 60. Respective mean RBC counts in male mice on day 60 (Figure 3) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 18% (8.38 × 10^6^/_L; P≤0.01), 26% (7.62 × 10^6^/_L; P≤0.01), and 34% (6.81 × 10^6^/_L; P≤0.01) lower than the mean (10.27 × 10^6^/_L) in the control group. Respective mean RBC counts on day 60 for female mice (Figure 4) treated with the same combinations were approximately 16% (7.94 × 10^6^/_L; P≤0.01), 28% (6.83 × 10^6^/_L; P≤0.01), and 26% (6.97 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.48 × 10^6^/_L) for the control group. Only one blood sample was available for evaluation on day 60 in the female high-dose combination group due to mortality. At the time of terminal sacrifice (days 92 to 95), the anemia in mice of both sexes was similar to that on day 60. On days 92 to 95, respective mean RBC counts in male mice (Figure 3) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 22% (7.70 × 10^6^/_L; P≤0.01), 27% (7.19 × 10^6^/_L; P≤0.01), and 33% (6.59 × 10^6^/_L; P≤0.01) lower than the mean RBC count (9.83 × 10^6^/_L) for the controls. Respective mean RBC counts for the female groups treated with the same doses were approximately 23% (7.40 × 10^6^/_L; P≤0.01), 27% (7.07 × 10^6^/_L; P≤0.01), and 35% (6.26 × 10^6^/_L; P≤0.01) lower than the mean (9.63 × 10^6^/_L) in the control group. In general, lower HGB and HCT values paralleled the treatment-related declines in RBC counts at all of the bleeding intervals (Table B1). However, the declines in HGB and HCT values were not as marked as the RBC counts because of macrocytic erythrocytes.

In general, treatment-related elevations in MCV and MCH values accompanied the anemia in male and female mice on days 30, 60, and 92 to 95 (Table B1). On day 30, respective mean MCV values in male mice (Figure 5) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 8% (52.3 fL; P≤0.01), 13% (54.9 fL; P≤0.01), and 15% (55.9 fL; P≤0.01) higher than the mean MCV value (48.5 fL) in the control group. Corresponding MCH values were approximately 7% (17.4 pg; P≤0.01), 11% (18.1 pg; P≤0.01), and 13% (18.4 pg; P≤0.01) higher than the mean (16.3 pg) for the controls. For the female groups treated with 100 or 200 mg/kg AZT + 150 mg/kg isoniazid, respective mean MCV values (Figure 6) were approximately 12% (55.3 fL; P≤0.01) and 13% (55.7 fL; P≤0.01) higher than the mean MCV value (49.5 fL) in the control group. Corresponding mean MCH values were approximately 8% (17.9 pg) and 5% (17.3 pg) higher than the mean MCH value (16.5 pg) for the controls. Significant (P≤0.05) increases in MCV and MCH values did not occur in the high-dose female combination group on day 30. A treatment-related macrocytosis was also prevalent in mice of both sexes on day 60. Respective mean MCV values on day 60 for male mice (Figure 5) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 9% (52.6 fL; P≤0.01), 14% (55.3 fL; P≤0.01), and 20% (58.0 fL; P≤0.01) higher than the mean MCV value (48.3 fL) in the control group. Corresponding mean MCH values were approximately 7% (17.3 pg; P≤0.01), 10% (17.9 pg; P≤0.01), and 15% (18.7 pg; P≤0.01) higher than the mean MCH value (16.2 pg) in the control group. For the female groups treated identically, respective mean MCV values (Figure 6) were approximately 15% (54.7 fL; P≤0.01), 20% (57.2 fL; P≤0.01), and 23% (58.3 fL; P≤0.01) higher than the mean MCV value (47.5 fL) in the female control group. Corresponding mean MCH values were approximately 13% (18.0 pg; P≤0.01), 18% (18.9 pg; P≤0.01), and 21% (19.4 pg; P≤0.01) higher than the mean MCH value (16.0 pg) for the controls. The macrocytosis was even more pronounced at the time of terminal sacrifice (days 92 to 95). Respective mean MCV values on days 92 to 95 in male groups (Figure 5) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 14% (53.4 fL; P≤0.01), 18% (55.1 fL; P≤0.01), and 26% (58.8 fL; P≤0.01) higher than the mean MCV value (46.7 fL) in the control group. Corresponding mean MCH values were approximately 11% (17.5 pg; P≤0.01), 15% (18.1 pg; P≤0.01), and 20% (18.9 pg; P≤0.01) higher than the mean MCH value (15.8 pg) in the control group. For the female groups treated identically, respective mean MCV values (Figure 6) were approximately 17% (54.8 fL; P≤0.01), 20% (56.3 fL; P≤0.01), and 30% (60.8 fL; P≤0.01) higher than the mean (46.8 fL) for the control group. Corresponding mean MCH values were approximately 12% (17.8 pg; P≤0.01), 16% (18.4 pg; P≤0.01), and 21% (19.3 pg; P≤0.01) higher than the mean MCH value (15.9 pg) for the controls. Minor statistically significant (P≤0.05 to P≤0.01) declines in MCHC values occurring in mice of both sexes (Table B1) were not considered to be biologically significant.

Administration of AZT + isoniazid resulted in an initial reticulocytopenia (day 4) in all combination treatment groups of both sexes, followed by a rebound in reticulocyte counts on days 30, 60, and 92 to 95 (Table B1). The severity of the reticulocytopenia was greater than that induced by AZT alone. Respective mean reticulocyte counts on day 4 in male mice (Figure 7) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 33% (2.6 × 10^5^/_L; P≤0.01), 38% (2.4 × 10^5^/_L; P≤0.01), and 64% (1.4 × 10^5^/_L; P≤0.01) lower than the mean reticulocyte count (3.9 × 10^5^/_L) in the control group. For the female groups (Figure 8) treated identically, respective mean reticulocyte counts were approximately 41% (1.6 × 10^5^/_L; P≤0.01), 63% (1.0 × 10^5^/_L; P≤0.01), and 74% (0.7 × 10^5^/_L; P≤0.01) lower than the mean reticulocyte count (2.7 × 10^5^/_L) in the control group. Reticulocyte counts rebounded in mice of both sexes by day 30. Respective mean reticulocyte counts on day 30 for male mice (Figure 7) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.2 times (3.5 × 10^5^/_L), 1.3 times (4.0 × 10^5^/_L; P≤0.01), and 1.6 times (4.7 × 10^5^/_L; P≤0.01) the mean (3.0 × 10^5^/_L) in the male control group. For the female groups treated identically (Figure 8), respective mean reticulocyte counts had returned to a normal range for all groups except the group treated with 400 mg/kg AZT + 100 mg/kg isoniazid; this group had approximately 2.1 times (6.4 × 10^5^/_L; P≤0.01) more reticulocytes than the mean (3.0 × 10^6^/_L) in the control group. On day 60, the rebound in reticulocyte counts was more pronounced in male mice than in female mice. Respective mean reticulocyte counts on day 60 (Figure 7) for male groups treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.3 times (4.0 × 10^5^/_L; P≤0.01), 1.3 times (4.1 × 10^5^/_L; P≤0.01), and 1.4 times (4.2 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.1 × 10^5^/_L) in the control group. Female groups treated identically did not have significant (P≤0.05) elevations in reticulocyte counts, although prominent macrocytosis (elevated MCV values) was present. On day 60, significant increases in reticulocyte counts only occurred in the female group (Figure 8) treated with 400 mg/kg AZT + 50 mg/kg isoniazid, which had a reticulocyte count approximately 1.5 times (4.9 × 10^5^/_L; P≤0.01) the mean (3.3 × 10^5^/_L) in the controls. Reticulocytosis also occurred in mice of both sexes at the time of terminal sacrifice. Respective mean reticulocyte counts on days 92 to 95 (Figure 7) for male mice treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.4 times (5.0 × 10^5^/_L; P≤0.01), 1.5 times (5.4 × 10^5^/_L; P≤0.01), and 1.5 times (5.5 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.7 × 10^5^/_L) in the controls. For the female groups treated identically (Figure 8), respective mean reticulocyte counts on days 92 to 95 were approximately 1.3 times (4.2 × 10^5^/_L), 1.5 times (4.9 × 10^5^/_L; P≤0.05), and 2.1 times (7.1 × 10^5^/_L; P≤0.01) the mean reticulocyte count (3.3 × 10^5^/_L) in the control group.

In general for the male groups treated with combinations of AZT and isoniazid, significant (P≤0.05 to P≤0.01) increases in reticulocyte counts correlated well with significant elevations (P≤0.01) in MCV values on days 30, 60, and 92 to 95. All male combination treatment groups had significant (P≤0.01) increases in MCV values at all three bleeding intervals and only four of these combination treatment groups did not have significant (P≤0.05) increases in reticulocyte counts. Significant (P≤0.05) increases in reticulocyte counts did not occur in male groups on day 30 treated with 100 mg/kg AZT + 50, 100, or 150 mg/kg isoniazid and on day 60 in the group treated with 100 mg/kg AZT + 100 mg/kg isoniazid.

The correlation between macrocytosis and reticulocytosis was not as good in female mice treated with combinations of AZT and isoniazid. With the exception of the highest dose combination group on day 30, significant (P≤0.01) increases in MCV values occurred in all female combination groups at all bleeding intervals. On day 30, significant increases in reticulocyte counts did not occur in the female groups treated with 100 mg/kg AZT + 50, 100, or 150 mg/kg isoniazid, 200 mg/kg AZT + 150 mg/kg isoniazid, or 400 mg/kg AZT + 150 mg/kg isoniazid. On day 60, with the exception of the female group treated with 400 mg/kg AZT + 50 mg/kg isoniazid, significant increases (P≤0.05) in reticulocyte counts did not occur with combination therapy. At the time of terminal sacrifice, the female groups treated with 100 mg/kg AZT + 50, 100, or 150 mg/kg isoniazid and the groups treated with 200 mg/kg AZT + 50 or 100 mg/kg isoniazid did not have significant increases (P>0.05) in reticulocyte counts. The lack of correlation between elevated MCV values and elevated reticulocyte counts implies an etiology other than increased reticulocyte counts for the macrocytosis. Administration of AZT and isoniazid combinations to male and female mice resulted in elevated platelet counts on days 30, 60, and 92 to 95 (Table B1). In general, the incidence and severity of the thrombocytosis were greater than induced by AZT therapy alone. On day 30, thrombocytosis occurred in two of the three male groups treated with AZT + 150 mg/kg isoniazid. Respective mean platelet counts on day 30 in the male groups (Figure 9) treated with 100 or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.2 times (1,411 × 10^3^/_L; P≤0.05) and 1.4 times (1,664 × 10^3^/_L; P≤0.01) the mean platelet count (1,165 × 10^3^/_L) for the controls. Thrombocytosis occurred on day 30 in the three female groups (Figure 10) treated with 400 mg/kg AZT + 50, 100, or 150 mg/kg isoniazid. Respective mean platelet counts were approximately 1.4 times (1,408 × 10^3^/_L; P≤0.05), 1.3 times (1,379 × 10^3^/_L; P≤0.05), and 2.2 times (2,273 × 10^3^/_L; P≤0.01) the mean platelet count (1,023 × 10^3^/_L) for the female controls. Thrombocytosis was more prominent on day 60 in mice of both sexes. Respective mean platelet counts on day 60 in male groups (Figure 9) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.2 times (1,456 × 10^3^/_L), 1.3 times (1,666 × 10^3^/_L; P≤0.01), and 1.5 times (1,822 × 10^3^/_L; P≤0.01) the mean platelet count (1,257 × 10^3^/_L) in the male control group. Significant (P≤0.05 to P≤0.01) elevations in platelet counts also occurred on day 60 in the male groups treated with 100 or 200 mg/kg AZT + 100 mg/kg isoniazid and with 400 mg/kg AZT + 50 or 100 mg/kg isoniazid. Respective mean platelet counts on day 60 for female mice (Figure 10) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.1 times (1,286 × 10^3^/_L), 1.3 times (1,458 × 10^3^/_L; P≤0.01), and 1.3 times (1,502 × 10^3^/_L) the mean platelet count (1,158 × 10^3^/_L) for the female controls. Significant elevations (P≤0.05 to P≤0.01) in platelet counts also occurred on day 60 in female groups treated with 400 mg/kg AZT + 50 and 100 mg/kg isoniazid. Treatment-related elevations in platelet counts also occurred in mice of both sexes at the time of terminal sacrifice (days 92 to 95). Respective mean platelet counts on days 92 to 95 in male groups (Figure 9) treated with 100, 200, or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 1.2 times (1,442 × 10^3^/_L), 1.2 times (1,456 × 10^3^/_L; P≤0.05), and 1.2 times (1,518 × 10^3^/_L; P≤0.01) the mean platelet count (1,222 × 10^3^/_L) in the male controls. Significant (P≤0.05 to P≤0.01) elevations also occurred in the male groups treated with 200 or 400 mg/kg AZT in combination with 50 or 100 mg/kg isoniazid. For the female mice (Figure 10) receiving combination therapy, thrombocytosis occurred in the groups treated with 400 mg/kg AZT + 50, 100, or 150 mg/kg isoniazid. Respective mean platelet counts were approximately 1.3 times (1,547 × 10^3^/_L; P≤0.01), 1.3 times (1,543 × 10^3^/_L; P≤0.01) and 1.3 times (1,628 × 10^3^/_L; P≤0.01) the mean platelet count (1,214 × 10^3^/_L) in the female control group.

Although not statistically (P≤0.05) significant, white blood cell (WBC) counts in the male combination treatment groups tended to be low (Table B1). On days 30, 60, and 92 to 95, respective mean WBC counts for male mice treated with 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 20% (7.20 × 10^3^/_L), 24% (4.20 × 10^3^/_L), and 32% (3.75 × 10^3^/_L) lower than the respective means (8.99, 5.53, and 5.49 × 10^3^/_L) for the male controls. Evaluation of the differential data revealed slight declines in granulocytes and mononuclear cells. For the female mice receiving combination therapy (Table B1), a compound-related leukopenia occurred on day 30. Respective mean WBC counts in female groups treated with 200 or 400 mg/kg AZT + 150 mg/kg isoniazid were approximately 27% (5.74 × 10^3^/_L; P≤0.05) and 40% (4.75 × 10^3^/_L; P≤0.01) lower than the mean (7.91 × 10^3^/_L) in the female controls. Evaluation of the differential data revealed that the leukopenia involved predominantly lymphocytes, monocytes, and neutrophils. Respective mean lymphocyte counts for the same treatment groups were approximately 27% (4.81 × 10^3^/_L; P≤0.05) and 38% (4.08 × 10^3^/_L; P≤0.01) lower than the mean lymphocyte count (6.59 × 10^3^/_L) for the control group. Although not statistically (P≤0.05) significant, the mean neutrophil count in the high-dose combination group was approximately 39% (0.51 × 10^3^/_L) lower than the mean (0.83 × 10^3^/_L) in the control group. The significant (P≤0.05) declines in monocyte counts were not believed to be biologically significant because of the low number of this cell type normally present in the differential. Significant (P≤0.05) declines in WBC, neutrophil, and lymphocyte counts did not occur in female combination groups on days 60 and 92 to 95; however, slight downward trends were present.

### Clinical Chemistry

Administration of AZT (100, 200, and 400 mg/kg per day) and isoniazid (50, 100, and 150 mg/kg per day) separately and in various combinations did not result in any biologically significant alterations in the clinical chemistry parameters (Table B2) evaluated in male or female mice at any of the scheduled bleeding intervals (days 4, 30, 60, and terminal sacrifice).

FIGURE 3 Mean Red Blood Cell Counts for Male Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicates standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

FIGURE 4 Mean Red Blood Cell Counts for Female Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

a Value for one mouse that survived to Day 60

FIGURE 5 Mean Corpuscular Volume for Male Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

FIGURE 6 Mean Corpuscular Volume for Female Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

a Value for one mouse that survived to Day 60

FIGURE 7 Mean Reticulocyte Counts for Male Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

FIGURE 8 Mean Reticulocyte Counts for Female Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

a Negative standard deviation not shown as it extends beyond the chart boundaries

b Value for one mouse that survived to Day 60

FIGURE 9 Mean Platelet Counts for Male Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

FIGURE 10 Mean Platelet Counts for Female Mice in the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Bars indicate standard deviation

* Significantly different (P<0.05) from control group using ANOVA followed by Dunnett’s procedure

** Significantly different (P<0.01) from control group using ANOVA followed by Dunnett’s procedure

a Value for one mouse that survived to Day 60

## Reproductive tissue evaluation and estrous cycle characterization

Administration of AZT alone, isoniazid alone, or combinations of AZT and isoniazid had no significant effect (P≤0.05) on left caudal, epididymal, or testicular weights, total spermatid heads per gram of testis, epididymal sperm density, or epididymal sperm motility (Table C1). Although not statistically significant, marginal declines in epididymal sperm motility occurred in male groups treated with 200 or 400 mg/kg AZT alone.

For female mice, the administration of AZT alone, isoniazid alone, or combinations of AZT and isoniazid had no effect on the average estrous cycle length (Table C2). Results of a two-way analysis of variance, however, indicated a significant (P≤0.0025) increase in the duration of estrus due to isoniazid treatment.

## Necropsy Observations

Necropsy findings possibly attributable to treatment were limited to thin, pale carcass in three female mice and small spleen in one female mouse in the group treated with 400 mg/kg AZT + 150 mg/kg isoniazid. Other findings occurring with a random distribution and believed to be incidental were focus on the spleen, focus on the liver, nodule on the liver, small testis, cyst on the ovary, dark clitoral gland, mass in the lung, diverticulum of the jejunum, alopecia, and opaque eye.

## Histopathologic Observations

Representative microscopic lesions resulting from administration of AZT and isoniazid are illustrated in Plates 1 through 6, which are summarized in Table 2. Target tissues included the bone marrow, liver, and spleen of male and female mice. Statistical results include dose-response effects of AZT and isoniazid compared to the vehicle control group as well as significant dose-response effects compared to AZT or isoniazid alone.

PLATE 1 Bone marrow from a control female mouse showing no treatment-related lesions. (×400)

PLATE 2 Bone marrow from a female mouse treated with 400 mg/kg AZT + 150 mg/kg isoniazid showing moderate cellular depletion. (×400)

PLATE 3 Spleen from a control female mouse showing no treatment-related lesions. (×200)

PLATE 4 Spleen from a female mouse treated with 400 mg/kg AZT + 150 mg/kg isoniazid showing moderate hematopoietic cell proliferation. (×200)

PLATE 5 Liver from a control male mouse showing no treatment-related lesions. (×400)

PLATE 6 Liver from a male mouse treated with 400 mg/kg AZT + 150 mg/kg isoniazid showing mild hepatocellular hypertrophy. (×400)

TABLE 2 List of Photomicrographs (Plates) of Treatment-Related Lesions in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Tissue | Magnification | Plate Number | Lesion
0 + 0 | Bone Marrow | ×400 | 1 | None (control)
400 + 150 | Bone Marrow | ×400 | 2 | Cellular depletion, moderate
0 + 0 | Spleen | ×200 | 3 | None (control)
400 + 150 | Spleen | ×200 | 4 | Hematopoietic cell proliferation, moderate
0 + 0 | Liver | ×400 | 5 | None (control)
400 + 150 | Liver | ×400 | 6 | Hepatocellular hypertrophy, mild

a AZT + isoniazid in mg/kg/day

### Bone Marrow Lesions

Cellular depletion of the bone marrow occurred in male and female mice treated with 400 mg/kg AZT alone (Table 3). Administration of isoniazid alone did not result in bone marrow depletion. Administration of AZT and isoniazid combinations to male and female mice resulted in an increase in the incidence (Table 3) of bone marrow depletion as well as an increase in the severity in females (Tables 3 and 4). Criteria for severity of bone marrow lesions were as follows:

- Minimal - Depletion of approximately 5% of the hematopoietic cells of the bone marrow
- Mild - Depletion of approximately 6% to 20% of the hematopoietic cells of the bone marrow
- Moderate - Depletion of approximately 21% to 50% of the hematopoietic cells of the bone marrow
- Marked - Depletion of more than 50% of the hematopoietic cells of the bone marrow.

TABLE 3 Incidence and Severity of Cellular Depletion of Bone Marrow in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Males | | Females
Dose^a^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^
0+0 | 0/10 | — | 0/10 | —
100+0 | 0/10 | — | 0/10 | —
200+0 | 0/10 | — | 0/10 | —
400+0 | 4/10 | 1.0 | 8/10 | 1.1
0+50 | 0/10 | — | 0/10 | —
100+50 | 0/10 | — | 1/10 | 1.0
200+50 | 3/10 | 1.0 | 4/10 | 1.0
400+50 | 8/10 | 1.0 | 8/10 | 1.3
0+100 | 0/10 | — | 0/10 | —
100+100 | 1/10 | 1.0 | 0/10 | —
200+100 | 3/10 | 1.0 | 6/10 | 1.0
400+100 | 10/10 | 1.0 | 8/10 | 1.1
0+150 | 0/10 | — | 0/10 | —
100+150 | 3/10 | 1.0 | 5/10 | 1.0
200+150 | 9/10 | 1.0 | 9/10 | 1.0
400+150 | 8/10 | 1.0 | 8/10 | 2.1

a AZT + isoniazid in mg/kg/day

b Number of animals in group with lesion/number of animals with tissue examined microscopically

c Mean severity (1=minimal, 2=mild, 3=moderate, 4=marked) for mice with the lesion

When compared to groups treated with AZT alone (100, 200, or 400 mg/kg), significant increases in severity (P≤0.05 to P≤0.01) occurred in female mice treated with 100 mg/kg AZT + 150 mg/kg isoniazid, female mice treated with 200 mg/kg AZT + 50 or 100 mg/kg isoniazid, male and female groups treated with 200 mg/kg AZT + 150 mg/kg isoniazid, and the male group treated with 400 mg/kg AZT + 100 mg/kg isoniazid (Table 4). Compared to groups treated with isoniazid alone (50, 100, or 150 mg/kg), significant increases in severity (P≤0.05 to P≤0.01) occurred in male and female groups treated with 200 or 400 mg/kg AZT + 50 or 150 mg/kg isoniazid, males treated with 400 mg/kg AZT + 100 mg/kg isoniazid, and female groups receiving 200 or 400 mg/kg AZT + 100 mg/kg isoniazid (Table 4). The peak mean severity occurred in the female group treated with 400 mg/kg AZT + 150 mg/kg isoniazid. In general, the enhanced severity of bone marrow depletion (P≤0.05 to P≤0.01) in groups receiving combination therapy corresponded with the increased severity of anemia.

TABLE 4 Statistical Analysis of Mean Severity of Cellular Depletion of Bone Marrow in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^d^ | Mean^c^ | S.E. | Ratio^d^
0+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+0 | 0.000 | 0.000 | | 0.000 | 0.000
200+0 | 0.000 | 0.000 | | 0.000 | 0.000
400+0 | **0.400 | 0.163 | | **0.900 | 0.180
| Trend^e^ | + (P=0.005) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
100+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+50 | 0.000 | 0.000 | | 0.100 | 0.100
100+100 | 0.100 | 0.100 | | 0.000 | 0.000
100+150 | 0.300 | 0.153 | | **0.500 | 0.167
| Trend^e^ | + (P=0.020) | | Trend^e^ | + (P=0.006)
| Test Used^f^ | Dunn | | Test Used^f^ | Shirley
200+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
200+50 | 0.300 | 0.153 | | *0.400 | 0.163
200+100 | 0.300 | 0.153 | | **0.600 | 0.163
200+150 | **0.900 | 0.100 | | **0.900 | 0.100
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
400+0 | 0.400 | 0.163 | — | 0.900 | 0.180 | —
400+50 | 0.800 | 0.133 | 200 | 1.000 | 0.258 | 111
400+100 | **1.000 | 0.000 | 250 | 0.900 | 0.180 | 100
400+150 | 0.800 | 0.133 | 200 | 1.700 | 0.396 | 189
| Trend^e^ | + (P=0.024) | | Trend^e^ | + (P=0.157)
| Test Used^f^ | Dunn | | Test Used^f^ | Dunn
0+50 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+50 | 0.000 | 0.000 | | 0.100 | 0.100
200+50 | *0.300 | 0.153 | | *0.400 | 0.163
400+50 | **0.800 | 0.133 | | **1.000 | 0.258
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+100 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+100 | 0.100 | 0.100 | | 0.000 | 0.000
200+100 | 0.300 | 0.153 | | **0.600 | 0.163
400+100 | **1.000 | 0.000 | | **0.900 | 0.180
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+150 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+150 | 0.300 | 0.153 | | *0.500 | 0.167
200+150 | **0.900 | 0.100 | | **0.900 | 0.100
400+150 | **0.800 | 0.133 | | **1.700 | 0.396
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley

a Severity grade presented as mean severity (0=not present, 1=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S.E.) for all mice in the group, including those with no lesion.

b AZT + isoniazid in mg/kg/day

c n=10

d (Dosed group mean/control group mean) × 100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Spleen Lesions

Hematopoietic cell proliferation or hyperplasia in the red pulp of the spleen (above background levels of normal extramedullary hematopoiesis) occurred in all male and female groups treated with AZT alone or in combination with isoniazid and in all female groups treated with isoniazid alone (Table 5). Extramedullary hematopoiesis (grade 0 for hematopoietic cell proliferation) consisting of megakaryocytes, foci of erythroid precursors, and large granulocytic precursors is a normal occurrence in the red pulp of the spleen of mice (Maronpot et al., 1999). Criteria for severity grades for hematopoietic cell proliferation in the spleen were as follows:

- Minimal - Approximately 15% of the red pulp is occupied by hematopoietic cells
- Mild - Approximately 16% to 50% of the red pulp is occupied by hematopoietic cells
- Moderate - Approximately 51% to 90% of the red pulp is occupied by hematopoietic cells
- Marked - Approximately 91% to 100% of the red pulp is occupied by hematopoietic cells.

Compared to the vehicle control groups, the degree of severity (Table 6) of splenic hematopoietic cell proliferation was significant (P≤0.01) in male groups treated with 100, 200, or 400 mg/kg AZT alone and in female groups treated with 200 or 400 mg/kg AZT alone. For mice treated with isoniazid alone, splenic hematopoiesis was significant (P≤0.01) only in the female group treated with 50 mg/kg when compared to the vehicle controls. When compared to groups treated with AZT alone (100, 200, or 400 mg/kg), splenic hematopoiesis was significant (P≤0.05 to P≤0.01) in male mice treated with 100 or 200 mg/kg AZT in combination with 100 or 150 mg/kg isoniazid and in female mice treated with 100 mg/kg AZT + 150 mg/kg isoniazid (Table 6). When compared to groups treated with isoniazid alone (50, 100, or 150 mg/kg), splenic hematopoiesis was significant (P≤0.01) in all male groups receiving combination therapy and in female groups treated with 100, 200, or 400 mg/kg AZT + 100 mg/kg isoniazid and with 100 mg/kg AZT + 150 mg/kg isoniazid (Table 6). In general, splenic hematopoiesis occurred with increased severity in groups with anemia and likely reflected a compensatory response to the anemia.

TABLE 5 Incidence and Severity of Hematopoietic Cell Proliferation in the Spleen in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Males | | Females
Dose^a^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^
0+0 | 0/10 | — | 1/10 | 1.0
100+0 | 7/10 | 1.1 | 4/10 | 1.8
200+0 | 8/10 | 1.0 | 8/10 | 1.6
400+0 | 10/10 | 1.6 | 9/10 | 2.1
0+50 | 0/10 | — | 8/10 | 1.5
100+50 | 7/10 | 1.6 | 8/10 | 2.1
200+50 | 10/10 | 1.4 | 8/10 | 2.0
400+50 | 10/10 | 1.8 | 8/10 | 2.5
0+100 | 0/10 | — | 5/10 | 1.0
100+100 | 10/10 | 1.9 | 9/10 | 2.0
200+100 | 10/10 | 2.1 | 10/10 | 2.2
400+100 | 10/10 | 1.6 | 9/10 | 2.1
0+150 | 0/10 | — | 2/10 | 1.0
100+150 | 10/10 | 1.9 | 9/10 | 2.2
200+150 | 10/10 | 1.7 | 9/10 | 1.1
400+150 | 9/10 | 2.0 | 6/10 | 2.7

a AZT + isoniazid in mg/kg/day

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity (1=minimal, 2=mild, 3=moderate, and 4=marked) for mice with the lesion.

TABLE 6 Statistical Analysis of Mean Severity of Hematopoietic Cell Proliferation in the Spleen in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^d^ | Mean^c^ | S.E. | Ratio^d^
0+0 | 0.000 | 0.000 | — | 0.100 | 0.100 | —
100+0 | **0.800 | 0.200 | | 0.700 | 0.335 | 700
200+0 | **1.000 | 0.211 | | **1.300 | 0.260 | 1300
400+0 | **1.600 | 0.163 | | **1.900 | 0.314 | 1900
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+0 | 0.000 | 0.000 | — | 0.100 | 0.100 | —
0+50 | 0.000 | 0.000 | | **1.300 | 0.300 | 1300
0+100 | 0.000 | 0.000 | | 0.500 | 0.167 | 500
0+150 | 0.000 | 0.000 | | 0.200 | 0.133 | 200
| Trend^e^ | (P=1.000) | | Trend^e^ | − (P=0.739)
| Test Used^f^ | Dunn | | Test Used^f^ | Dunn
100+0 | 0.800 | 0.200 | — | 0.700 | 0.335 | —
100+50 | 1.100 | 0.277 | 138 | 1.700 | 0.396 | 243
100+100 | **1.900 | 0.233 | 238 | 1.800 | 0.291 | 257
100+150 | **2.000 | 0.149 | 250 | *2.000 | 0.258 | 286
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P=0.014)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
200+0 | 1.000 | 0.211 | — | 1.300 | 0.260 | —
200+50 | 1.400 | 0.163 | 140 | 1.600 | 0.371 | 123
200+100 | **2.100 | 0.100 | 210 | 2.200 | 0.249 | 169
200+150 | **1.700 | 0.153 | 170 | 1.200 | 0.200 | 92
| Trend^e^ | + (P=0.002) | | Trend^e^ | + (P=0.960)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
400+0 | 1.600 | 0.163 | — | 1.900 | 0.314 | —
400+50 | 1.800 | 0.133 | 113 | 2.000 | 0.394 | 105
400+100 | 1.600 | 0.163 | 100 | 1.900 | 0.277 | 100
400+150 | 1.800 | 0.291 | 113 | 1.400 | 0.476 | 74
| Trend^e^ | + (P=0.571) | | Trend^e^ | − (P=0.470)
| Test Used^f^ | Dunn | | Test Used^f^ | Dunn
0+50 | 0.000 | 0.000 | — | 1.300 | 0.300 | —
100+50 | **1.100 | 0.277 | | 1.700 | 0.396 | 131
200+50 | **1.400 | 0.163 | | 1.600 | 0.371 | 123
400+50 | **1.800 | 0.133 | | 2.000 | 0.394 | 154
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P=0.215)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
0+100 | 0.000 | 0.000 | — | 0.500 | 0.167 | —
100+100 | **1.900 | 0.233 | | **1.800 | 0.291 | 360
200+100 | **2.100 | 0.100 | | **2.200 | 0.249 | 440
400+100 | **1.600 | 0.163 | | **1.900 | 0.277 | 380
| Trend^e^ | + (P=0.001) | | Trend^e^ | + (P=0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+150 | 0.000 | 0.000 | — | 0.200 | 0.133 | —
100+150 | **2.000 | 0.149 | | **2.000 | 0.258 | 1000
200+150 | **1.700 | 0.153 | | 1.200 | 0.200 | 600
400+150 | **1.800 | 0.291 | | 1.400 | 0.476 | 700
| Trend^e^ | + (P=0.001) | | Trend^e^ | + (P=0.096)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn

a Severity grade presented as mean severity (0=not present, 1=minimal, 2=mild, 3=moderate, 4=marked) and standard error (S.E.) for all mice in the group, including those with no lesion.

b AZT + isoniazid in mg/kg/day

c n=10

d (Dosed group mean/control group mean) × 100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Liver Lesions

A treatment-related pigmentation of the liver occurred in male groups treated with 100 or 150 mg/kg isoniazid alone or in combination with AZT and in female mice treated with 400 mg/kg AZT + 150 mg/kg isoniazid (Table 7). The liver pigmentation did not occur in groups treated with 50 mg/kg isoniazid alone or in groups treated with AZT alone or in combination with 50 mg/kg isoniazid. The pigment consisted of fine to coarse brown granules within the cytoplasm of hepatocytes and, to a lesser extent, Kupffer cells. The pigment resembled hemosiderin with routine hematoxylin and eosin stains, but when stained with Prussian Blue, was negative for iron (Sheehan and Hrapchak, 1980). The pigment occurred primarily in the paracentral and midzonal portions of the hepatic lobules with relative sparing of the periportal areas. Criteria for grading the pigmentation were as follows:

- Minimal - approximately 5% of the cytoplasm occupied by pigment
- Mild - approximately 6 to 15% of the cytoplasm occupied by pigment.

Compared to the vehicle control male group, the liver pigmentation was significant (P≤0.01) in male groups treated with 100 or 150 mg/kg isoniazid alone (Table 8). When compared to groups treated with AZT alone (100, 200, or 400 mg/kg), significant increases in pigmentation (P≤0.01) occurred in male groups treated with 100 or 200 mg/kg AZT in combination with 100 or 150 mg/kg isoniazid and in male and female groups treated with 400 mg/kg AZT + 150 mg/kg isoniazid. When compared to the male group treated with 100 mg/kg isoniazid alone, a significant decline (P≤0.01) in pigmentation occurred in the male group treated with 400 mg/kg AZT + 100 mg/kg isoniazid. The pigment was not identified but was considered possibly a metabolite of isoniazid.

Hypertrophy of hepatocytes occurred in male groups treated with 150 mg/kg isoniazid alone or in combination with 100, 200, or 400 mg/kg AZT (Table 7). The hypertrophy occurred in the same areas of the liver lobules as the pigmentation. Criteria for grading the severity of hypertrophy were as follows:

- Minimal - an increase in the size of hepatocytes by approximately 15%
- Mild - an increase in the size of hepatocytes by approximately 16% to 25%.

Hepatocellular hypertrophy was significant (P≤0.05) only in the group treated with 400 mg/kg AZT + 150 mg/kg isoniazid when compared to the group treated with 400 mg/kg AZT alone (Table 9).

TABLE 7 Incidence and Severity of Hepatocyte Pigmentation and Hypertrophy in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Pigmentation | | | | Hypertrophy
Dose^a^ | Males | | Females | | Males | | Females
Dose^a^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^
0+0 | 0/10 | — | 0/10 | — | 0/10 | — | 0/10 | —
0+100 | 6/10 | 1.2 | 0/10 | — | 0/10 | — | 0/10 | —
100+100 | 6/10 | 1.0 | 0/10 | — | 0/10 | — | 0/10 | —
200+100 | 6/10 | 1.0 | 0/10 | — | 0/10 | — | 0/10 | —
400+100 | 0/10 | — | 0/10 | — | 0/10 | — | 0/10 | —
0+150 | 10/10 | 2.0 | 0/10 | — | 2/10 | 2.0 | 0/10 | —
100+150 | 10/10 | 1.7 | 0/10 | — | 2/10 | 2.0 | 0/10 | —
200+150 | 9/10 | 1.8 | 0/10 | — | 2/10 | 2.0 | 0/10 | —
400+150 | 9/10 | 1.7 | 4/10 | 1.0 | 3/10 | 2.0 | 0/10 | —

a AZT + isoniazid in mg/kg/day. Groups treated with AZT alone or AZT + 50 mg/kg isoniazid are not listed because lesions did not occur.

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity (1=minimal, 2=mild, 3=moderate, and 4=marked) for mice with the lesion.

TABLE 8 Statistical Analysis of Mean Severity of Hepatocyte Pigmentation in B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^b^ | Severity in Males^a^ | | | Severity in Females^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^d^ | Mean^c^ | S.E. | Ratio^d^
0+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+0 | 0.000 | 0.000 | | 0.000 | 0.000
200+0 | 0.000 | 0.000 | | 0.000 | 0.000
400+0 | 0.000 | 0.000 | | 0.000 | 0.000
| Trend^e^ | (P=1.000) | | Trend^e^ | (P=1.000)
| Test Used^f^ | Dunn | | Test Used^f^ | Dunn
0+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
0+50 | 0.000 | 0.000 | | 0.000 | 0.000
0+100 | **0.700 | 0.213 | | 0.000 | 0.000
0+150 | **2.000 | 0.149 | | 0.000 | 0.000
| Trend^e^ | + (P≤0.001) | | Trend^e^ | (P=1.000)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
100+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
100+50 | 0.000 | 0.000 | | 0.000 | 0.000
100+100 | **0.600 | 0.163 | | 0.000 | 0.000
100+150 | **1.700 | 0.260 | | 0.000 | 0.000
| Trend^e^ | + (P≤0.001) | | Trend^e^ | (P=1.000)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
200+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
200+50 | 0.000 | 0.000 | | 0.000 | 0.000
200+100 | **0.600 | 0.163 | | 0.000 | 0.000
200+150 | **1.600 | 0.267 | | 0.000 | 0.000
| Trend^e^ | + (P≤0.001) | | Trend^e^ | (P=1.000)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
400+0 | 0.000 | 0.000 | — | 0.000 | 0.000 | —
400+50 | 0.000 | 0.000 | | 0.000 | 0.000
400+100 | 0.000 | 0.000 | | 0.000 | 0.000
400+150 | **1.500 | 0.224 | | **0.400 | 0.163
| Trend^e^ | + (P≤0.001) | | Trend^e^ | + (P=0.005)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+100 | 0.700 | 0.213 | — | 0.000 | 0.000 | —
100+100 | 0.600 | 0.163 | 86 | 0.000 | 0.000
200+100 | 0.600 | 0.163 | 86 | 0.000 | 0.000
400+100 | **0.000 | 0.000 | 0 | 0.000 | 0.000
| Trend^e^ | − (P=0.008) | | Trend^e^ | (P=1.000)
| Test Used^f^ | Shirley | | Test Used^f^ | Dunn
0+150 | 2.000 | 0.149 | — | 0.000 | 0.000 | —
100+150 | 1.700 | 0.260 | 85 | 0.000 | 0.000
200+150 | 1.600 | 0.267 | 80 | 0.000 | 0.000
400+150 | 1.500 | 0.224 | 75 | **0.400 | 0.163
| Trend^e^ | − (P=0.150) | | Trend^e^ | + (P=0.005)
| Test Used^f^ | Dunn | | Test Used^f^ | Shirley

a Severity grade presented as mean severity (0=not present, 1=minimal, 2=mild) and standard error (S.E.) for all mice in the group, including those with no lesion.

b AZT + isoniazid in mg/kg/day

c n=10

d (Dosed group mean/control group mean) ×100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

TABLE 9 Statistical Analysis of Mean Severity of Hepatocyte Hypertrophy in Male B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^b^ | Severity in Males^a^
Dose^b^ | Mean^c^ | S.E. | Ratio^d^
0+0 | 0.000 | 0.000 | —
100+0 | 0.000 | 0.000
200+0 | 0.000 | 0.000
400+0 | 0.000 | 0.000
| Trend^e^ | (P=1.000)
| Test Used^f^ | Dunn
0+0 | 0.000 | 0.000 | —
0+50 | 0.000 | 0.000
0+100 | 0.000 | 0.000
0+150 | 0.400 | 0.267
| Trend^e^ | + (P=0.055)
| Test Used^f^ | Dunn
100+0 | 0.000 | 0.000 | —
100+50 | 0.000 | 0.000
100+100 | 0.000 | 0.000
100+150 | 0.400 | 0.267
| Trend^e^ | + (P=0.055)
| Test Used^f^ | Dunn
200+0 | 0.000 | 0.000 | —
200+50 | 0.000 | 0.000
200+100 | 0.000 | 0.000
200+150 | 0.400 | 0.267
| Trend^e^ | + (P=0.055)
| Test Used^f^ | Dunn
400+0 | 0.000 | 0.000 | —
400+50 | 0.000 | 0.000
400+100 | 0.000 | 0.000
400+150 | *0.600 | 0.306
| Trend^e^ | + (P=0.017)
| Test Used^f^ | Dunn
0+150 | 0.400 | 0.267 | —
100+150 | 0.400 | 0.267 | 100
200+150 | 0.400 | 0.267 | 100
400+150 | 0.600 | 0.306 | 150
| Trend^e^ | + (P=0.616)
| Test Used^f^ | Dunn

a Severity grade presented as mean severity (0=not present, 1=minimal, 2=mild) and standard error (S.E.) for all mice in the group, including those with no lesion.

b AZT + isoniazid in mg/kg/day

c n=10

d (Dosed group mean/control group mean) × 100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Other Lesions

Other lesions occurred with a random distribution across all treatment groups and were not believed to be related to treatment. Two female mice had benign teratomas of the ovary. Examples of nonneoplastic lesions believed to be incidental were suppurative inflammation in the lung, chronic inflammation in the skin and liver, bone marrow hyperplasia, perforated esophagus, pigment in the spleen, focal necrosis of the liver, cyst in the ovary and parathyroid, hydrometra, hemmorhage in the esophagus, accessory adrenal cortical nodule, epithelial hyperplasia in the forestomach, and atrophy of germinal epithelium in the testicle.