# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; Lot 1401-R-7) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a powder. Isoniazid (Lot 7232-74-02 RTI,) was manufactured by Fluka Chemical Corp. (Ronkonkoma, NY) and supplied as crystals. Identification of both compounds was confirmed by nuclear magnetic resonance and infrared spectroscopy. The purity of both AZT and isoniazid was determined by high-performance liquid chromatography to be greater than 99%.

The control article was an aqueous solution containing 0.5% methylcellulose. The methylcellulose (Lot 876672) was obtained from Fisher Scientific Co. (Pittsburgh, PA).

## Dose Formulations

The test articles were combined singly or in combination with the control article. The dosing formulations were then stirred until visually homogeneous.

Stability studies indicated that AZT/isoniazid formulations were stable for at least 30 days at refrigerated and ambient temperatures. Dosing formulations of AZT and isoniazid used in this study were stored refrigerated in the dark for a maximum of 23 days after mixing.

Samples of dosing formulations from each dose level from the first, midpoint, and final mixes were analyzed for concentration prior to dosing. Residual formulations taken from the same mixes after dosing were also analyzed. AZT and isoniazid formulations were homogeneous. Prior to dosing, the found concentrations of AZT ranged from 94.2% to 107% of the target concentrations; the found concentrations of isoniazid were 87.0% to 105%. Found concentrations of the residual formulations were 93.4% to 113% for AZT and 93.2% to 118% for isoniazid.

## Study Design

Male and female B6C3F_1_ mice were obtained from an NIEHS production colony at Taconic Laboratory Animals and Services (Germantown, NY) and were approximately 6 weeks old when placed on study. The mice were housed five per cage during quarantine before randomization and were housed individually (males) or five per cage (females) after randomization.

The mice were housed in polycarbonate cages with solid bottom and sides. The cages were suspended on stainless steel racks and heat-treated hardwood chips were used as the contact bedding. Appropriate environmental conditions, as listed in Table 1, were maintained in the animal rooms throughout quarantine and testing.

Blood samples were collected from five sentinel animals per sex at approximately 60 and 90 days as part of the Animal Disease Screening program. Results indicated that all animals were free of viral antibodies.

Acquired immune deficiency syndrome (AIDS) patients frequently receive combination therapy with isoniazid and AZT to treat tuberculosis, which is one of the complicating opportunistic infections in these immunologically suppressed individuals. At the present time, no acceptable alternatives to animal models provide adequate toxicity information regarding this combination therapy. The lowest dose level of isoniazid for the current study was set at 50 mg/kg per day because it was close to the clinically relevant therapeutic dose. The medium and high dose levels of isoniazid were set at 100 and 150 mg/kg per day to induce some measure of toxicity. Even though the reported LD_50_ dose for the mouse was 133 mg/kg (Benson et al., 1952), in a previous study with Swiss (CD-1^®^) mice, doses of isoniazid alone up to 150 mg/kg administered for 30 days did not cause significant toxicity. However, when administered in combination with AZT, the above doses of isoniazid increased the toxic effects of AZT (NIEHS, 1999). The selected AZT doses for this study were 100, 200, and 400 mg/kg per day. The human therapeutic dose for AZT is 10 mg/kg per day (PDR, 1999). The selected doses for the current study were 10, 20, and 40 times human doses, but on a body surface area basis, the doses were close to 1, 2, and 4 times the therapeutic dose (Freireich, et al., 1966). Results of previous toxicity studies conducted in mice have also demonstrated that measurable evidence of toxicity would be obtained at the levels of 100, 200, and 400 mg/kg AZT (NTP, 1999).

A brief summary of the study design is provided in Table 1. The B6C3F_1_ mouse was selected as the experimental animal because this animal model has previously been utilized for toxicity evaluations of this type by the NIEHS. The route of administration selected for this study was oral because this is the clinically relevant route used in humans. AZT and isoniazid were administered as a single dose formulation. The total daily dose was divided into two equal doses administered by gavage approximately 6 hours apart. Each group consisted of 20 mice per sex. Core animals (10/sex) were dosed daily for 92 to 95 consecutive days until the day prior to sacrifice. Clinical pathology animals (10/sex) were dosed until day 59. All mice were observed twice daily (morning and afternoon) for signs of mortality/moribundity.

On days 4, 30, and 60 for all clinical pathology animals and prior to sacrifice on days 92 to 95 for the core animals, blood was drawn from the retroorbital sinus for clinical pathology determinations. Vaginal cytology evaluations were conducted on all core study females on days 78 to 89, and sperm count, function, and motility were assessed on core study males on days 92 to 95. Surviving clinical pathology animals were euthanized on day 60 using 100% CO_2_ and discarded; surviving core study animals were sacrificed on days 92 to 95 using 100% CO_2_. A complete necropsy was conducted on all core study mice, early death clinical pathology animals, and females in the 400 + 150 mg/kg clinical pathology group. Selected organs (see Table 1) from core study animals were weighed.

### Reproductive Tissue Evaluation and Estrous Cycle Characterization

Samples of vaginal fluid were taken from females using a medicine dropper, moistened with 0.9% saline if necessary. Samples from 12 consecutive days per group were placed on two slides per animal and evaluated for relative frequency of estrous phases and the estrous cycle length. The left testis from each male was removed at necropsy and weighed. The left epididymis was weighed, then sperm samples were collected and mixed with modified Tyrode’s Solution on two prewarmed slides per animal. Slides were maintained at approximately 37° C and viewed under a light microscope to assess sperm motility. The distal cauda of the epididymis was weighed then placed in a petri dish containing phosphate-buffered saline, and the tissue was teased to release the contents. The final caudal epididymal sperm suspension was incubated for at least 15 minutes. An aliquot was then further diluted with saline solution and placed in a bath of hot water for at least one minute to kill the sperm. Sperm density was determined using a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Clinical Pathology

Blood was drawn on days 4, 30, and 60 from all mice in the clinical pathology groups and at terminal sacrifice from all mice in the core study groups for hematology and clinical chemistry determinations. All blood samples were taken from the retroorbital sinus under CO_2_/O_2_ (70/30) anesthesia and collected into tubes containing EDTA (hematology) or no anticoagulant (clinical chemistry). Animals were selected in random order for blood collection, and samples were analyzed in the order collected. Erythrocyte, platelet, and leukocyte counts, hematocrit, hemoglobin, mean corpuscular hemoglobin, mean corpuscular volume, mean corpuscular hemoglobin concentration, and leukocyte differentials were determined on whole blood using a Technicon H·1^™^ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite^™^ Flow Cytometer. Blood smears were prepared to evaluate erythrocyte and platelet morphologies and to manually verify leukocyte differentials and morphologies if necessary; platelet and erythrocyte morphological alterations were reported only in the raw data. Alanine aminotransferase (ALT), sorbitol dehydrogenase (SDH), alkaline phosphatase (ALP), aspartate aminotransferase (AST), and total bile acids (BILA) were determined using a Roche Cobas Fara^™^ automated analyzer.

### Histopathology

Histopathologic examination was performed on tissues listed in Table 1. A complete examination was performed on all core study control animals, all animals in the core groups that received the highest dose of each test article alone or in combination, core study females in the next lower combination dose groups, clinical pathology females in the highest dose combination group, and early deaths in all dose groups. Designated target organs and gross lesions were examined histopathologically for core study animals in the lower dose groups. Tissues were trimmed, embedded in paraffin, sectioned at 4 to 6 μm, and mounted on glass microscope slides. Slides were stained with hematoxylin and eosin or with periodic acid-Schiff (testes). All tissues were examined by light microscopy and results were described using a standard nomenclature.

TABLE 1 Experimental Design and Materials and Methods for the 13-Week Toxicity Study of AZT and Isoniazid Combinations in B6C3F_1_ Mice

- Study Laboratory; Southern Research Institute, Birmingham, AL; - Strain and Species; B6C3F_1_ mice; - Animal Source; Taconic Laboratory Animals and Services, Germantown, NY; - Time Held Before Study; 11–12 days (core study males and females, and clinical pathology males) or 18–19 days (clinical pathology females); - Age When Placed on Study; 42–43 days; - Date of First Dose; Core study groups: 8 February 1993; Clinical pathology groups: 15 or 16 February 1993 (males) or 22 or 23 February 1993 (females); - Date of Last Dose; Day prior to terminal sacrifice; - Date of Necropsy; Core study groups: 10–13 May 1993; Clinical pathology groups: 15 or 16 April 1993 (males) and 22 or 23 April 1993 (females); - Age at Terminal Necropsy; Core study groups: 133–136 days; Clinical pathology groups: 101–102 days; - Size of Study Groups; 10 males and 10 females per core study group and 10 males and 10 females per clinical pathology study group; - Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups in random order; - Method of Animal Identification; Microchip implant (Biomedic Data Systems, Inc., Maywood, NJ); - Diet; NIH-07 pelleted feed (Zeigler Bothers, Inc.; Gardners, PA) available ad libitum; fresh feed provided weekly or as neeeded; - Water; Tap water (Birmingham municipal supply) via automated watering system (Edstrom Industries, Inc.; Waterford, WI) available ad libitum; - Cages; Polycarbonate cages with solid bottom and sides (Lab Products, Inc.; Maywood, NJ); changed once weekly (individually housed mice) or twice weekly (group-housed mice); - Bedding; Heat-treated hardwood-chip bedding (P.J. Murphy Forest Products Corporation; Montville, NJ); changed once weekly (individually housed mice) or twice weekly (group-housed mice); - Cage Filters; Reemay spun-bonded polyester (Andico; Birmingham, AL), changed once every 2 weeks; - Racks; Stainless steel racks (Lab Products, Inc.; Maywood, NJ), changed once every 2 weeks; - Animal Room Environment; Temperature: 70.6° F ± 1.2° F; Relative humidity: 49.2% ± 5.2%; Fluorescent light: 12 hours fluorescent light/day; Room air: minimum of 10 changes per hour; - Doses; 15 combinations of AZT + isoniazid (mg per kg body weight per day) and a control group:; - Type and Frequency of Observations; Mortality/moribundity: twice daily; Clinical findings: once weekly (core study mice only); Body weights: once weekly (recorded for the clinical pathology mice only for determination of dosing volumes and not used for interpretation of body weight effects); - Clinical Pathology; Hematology and clinical chemistry evaluations were conducted on all core study animals at terminal sacrifice and on all clinical pathology animals on days 4, 30, and 60.; - Reproductive Tissue Evaluation; Conducted on all core study males at terminal sacrifice; - Estrous Cycle Characterization; Conducted on all core study females on days 78–89; - Necropsy and Histopathologic Examinations; Complete necropsies were performed on all core study animals, early death clinical pathology animals, and females in the 400 + 150 mg/kg clinical pathology group. All tissues were saved in formalin, except the right testis, which was saved in Bouin’s. The liver, right kidney, heart, lungs, thymus, and right testis of all core study mice sacrificed at the end of the study were weighed. Complete histopathologic processing was performed on all animals in the core control group, all early deaths in all dose groups, all animals in the 0 + 0, 0 + 150, 400 + 0, and 400 + 150 mg/kg core study groups, females in the 200 + 150 and 400 + 100 mg/kg core study groups, and females in the 400 + 150 mg/kg clinical pathology group. Tissues examined for a complete evaluation were adrenal glands, brain, clitoral glands, esophagus, femur, gallbladder, gross lesions, heart and aorta, large intestines, small intestines, kidneys, liver, lungs and bronchi, mandibular and mesenteric lymph nodes, mammary gland, nose, ovaries, pancreas, parathyroid glands, pituitary gland, preputial glands, prostate, salivary glands, seminal vesicle, spleen, stomach, right testis with epididymis, thymus, thyroid gland, tissue masses with regional lymph nodes, trachea, urinary bladder, and uterus. Gross lesions, bone marrow, liver, and spleen were processed in remaining core study dose groups.
  0 + 0 | 100 + 0 | 200 + 0 | 400 + 0
  0 + 50 | 100 + 50 | 200 + 50 | 400 + 50
  0 + 100 | 100 + 100 | 200 + 100 | 400 + 100
  0 + 150 | 100 + 150 | 200 + 150 | 400 + 150

## Statistical Methods

Group means and standard deviations were calculated for body weights, clinical pathology parameters, and terminal body and organ weights. Organ/body weight ratios were also calculated. Mean terminal body weights, mean organ weights, and organ/body weight ratios for each treated group were compared to those of the control group by a two-tailed Student’s t-test for each sex. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and treated groups. Terminal body weights were also evaluated using Jonckheere’s (1954) test for trend; if there was a trend, Williams’ (1971, 1972) test was applied, but if there was no trend in the data, Dunnett’s (1955) test was used. Dunnett’s test was also used for evaluation of differences in clinical pathology parameters for treated and control groups.

Organ weights associated with reproductive tissue evaluations, along with terminal body weights, were analyzed using a two-way analysis of variance. The primary evidence for a treatment-related effect was taken to be the statistical significance of a main effect in the analysis of variance, with no evidence of differences in the effects of AZT over the levels of isoniazid as indicated by the absence of a significant AZT by isoniazid interaction. Sperm measurements were first analyzed using a nonparametric test for interaction. If the interaction was not statistically significant, averages were taken for each drug over the levels of the other drug, and control and treated group means were compared using either Williams’ (1971, 1972) or Dunnett’s (1955) multiple comparison procedures. The choice between the two tests was based on the evidence of a dose-related trend in the data as assessed by Jonckheere’s test (1954). Williams’ test was applied if there was an indication of a trend (P<0.01), and Dunnett’s test was used in the absence of a trend. The outlier test of Dixon and Massey (1951) was employed to detect extreme values. No value selected by the outlier test was eliminated unless it was at least twice the next largest value or at most half of the next smallest value.

Treatment effects on estrous cycle data were investigated by applying a multivariate analysis of variance (using Wilke’s Criterion [Stevens, 1986] as the test statistic) to test for the simultaneous equality of measurements across dose levels. Since the data are proportions (the proportion of the observation period that an animal was in a given estrous phase), an arcsine transformation was used to bring the data into closer conformance with the normality assumptions required for the multivariate analysis of variance.

For histopathology data, the presence of dose effects and interaction between AZT and isoniazid was assessed using methods of generalized linear models (McCullagh and Nelder, 1989; Fahrmeir and Tutz, 1994). The dependent variables used were graded histopathological lesions indexed as 0 through 4. These indices were assumed to follow a multinomial distribution. A cumulative logit link function was used to relate a lesion to dose and interaction effects. When only two graded lesion indices were observed, the multinomial distribution reduced to a binomial distribution, in which case a logit link function was used. AZT and isoniazid dose effects and their interaction were investigated by analysis of deviance (Jonckheere, 1954). Statistical significance of main and interaction effects was assessed using P values obtained from likelihood ratio tests (Dunn, 1964; Shirley, 1977).