# APPENDIX C Reproductive Tissue Evaluations and Estrous Cycle Characterization

TABLE C1 Summary of Reproductive Tissue Evaluations for Male B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | Left Caudal Weight (g) | Left Epididymal Weight (g) | Left Testicular Weight (g)
0 + 0 | 0.0165 ± 0.0008 | 0.0422 ± 0.0018 | 0.1074 ± 0.0053
100 + 0 | 0.0182 ± 0.0026 (9) | 0.0477 ± 0.0022 (9) | 0.1150 ± 0.0033 (9)
200 + 0 | 0.0189 ± 0.0009 | 0.0445 ± 0.0013 | 0.1054 ± 0.0047
400 + 0 | 0.0189 ± 0.0008 | 0.0460 ± 0.0009 | 0.1118 ± 0.0031
0 + 50 | 0.0195 ± 0.0027 | 0.0459 ± 0.0028 | 0.1161 ± 0.0037
0 + 100 | 0.0194 ± 0.0018 | 0.0463 ± 0.0023 | 0.1134 ± 0.0018
0 + 150 | 0.0171 ± 0.0005 | 0.0439 ± 0.0006 | 0.1114 ± 0.0023
100 + 50 | 0.0184 ± 0.0016 | 0.0475 ± 0.0014 | 0.1174 ± 0.0034
100 + 100 | 0.0190 ± 0.0008 | 0.0463 ± 0.0007 | 0.1158 ± 0.0017
100 + 150 | 0.0178 ± 0.0006 | 0.0442 ± 0.0012 | 0.1081 ± 0.0053
200 + 50 | 0.0190 ± 0.0006 | 0.0464 ± 0.0013 | 0.1078 ± 0.0052
200 + 100 | 0.0192 ± 0.0007 | 0.0463 ± 0.0011 | 0.1123 ± 0.0021
200 + 150 | 0.0181 ± 0.0009 | 0.0441 ± 0.0015 | 0.1100 ± 0.0041
400 + 50 | 0.0183 ± 0.0008 | 0.0445 ± 0.0012 | 0.1048 ± 0.0050
400 + 100 | 0.0165 ± 0.0014 | 0.0425 ± 0.0022 | 0.0998 ± 0.0034 (9)^b^
400 + 150 | 0.0191 ± 0.0024 | 0.0498 ± 0.0046 | 0.1077 ± 0.0019
Dose^a^ | Epididymal Sperm Motility (%) | Epididymal Sperm Density (×10^6^) | Spermatid Heads Per Gram of Testis (×10^7^)
0 + 0 | 81.47 ± 1.92 | 1197.49 ± 110.27 | 20.49 ± 0.72
100 + 0 | 83.47 ± 0.75 (9) | 1505.20 ± 260.31 (9) | 19.44 ± 0.43 (9)
200 + 0 | 74.50 ± 7.75 | 1136.56 ± 92.27 | 21.39 ± 0.93
400 + 0 | 73.79 ± 8.22 | 1238.60 ± 85.11 | 19.55 ± 0.31
0 + 50 | 80.80 ± 1.31 | 1243.27 ± 149.66 | 19.68 ± 0.73
0 + 100 | 78.43 ± 2.33 | 1484.79 ± 93.67 | 21.23 ± 0.44
0 + 150 | 81.05 ± 1.00 | 1640.72 ± 104.39 | 20.90 ± 0.58
100 + 50 | 74.46 ± 8.29 | 1369.02 ± 261.22 | 19.88 ± 0.28
100 + 100 | 58.88 ± 9.62 | 1193.77 ± 140.75 | 19.38 ± 0.31
100 + 150 | 62.61 ± 10.51 | 1225.16 ± 91.11 | 19.67 ± 0.28
200 + 50 | 67.67 ± 7.65 | 1087.72 ± 98.26 | 21.20 ± 0.93
200 + 100 | 67.63 ± 7.80 | 1290.82 ± 43.99 | 20.71 ± 0.42
200 + 150 | 60.34 ± 10.69 | 1433.99 ± 97.03 | 20.46 ± 0.50
400 + 50 | 60.62 ± 8.72 | 1257.66 ± 153.83 | 19.99 ± 0.43
400 + 100 | 74.72 ± 3.96 | 1337.21 ± 87.85 (9)^b^ | 22.86 ± 0.49 (9)^b^
400 + 150 | 74.76 ± 7.46 | 1254.19 ± 183.83 | 21.33 ± 0.91

Note: All findings presented as mean value ± standard error; n=10 unless noted in parentheses.

a AZT + isoniazid in mg/kg/day

b Data for one animal excluded based on the outlier test of Dixon and Massey to detect extreme values.

TABLE C2 Summary of Estrous Cycle Evaluations for Female B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Dose^a^ | n | Estrous Cycle Length (days)^b^ | Relative Frequency of Estrous Stages (%)
Dose^a^ | n | Estrous Cycle Length (days)^b^ | Proestrus | Estrus^c^ | Metestrus | Diestrus
0+0 | 9 | 4.11 ± 0.07 | 21.7 | 27.5 | 17.5 | 33.3
100+0 | 9 | 4.61 ± 0.55 | 18.3 | 20.8 | 20.0 | 40.8
200+0 | 8 | 4.19 ± 0.13 | 19.2 | 22.5 | 20.0 | 38.3
400+0 | 10 | 4.70 ± 0.49 | 19.2 | 23.3 | 15.0 | 42.5
0+50 | 10 | 4.10 ± 0.10 | 18.3 | 24.2 | 21.7 | 35.8
0+100 | 7 | 4.71 ± 0.47 | 18.3 | 23.3 | 15.0 | 43.3
0+150 | 7 | 4.50 ± 0.19 | 19.0 | 28.6 | 14.3 | 38.1
100+0 | 9 | 4.39 ± 0.14 | 18.5 | 21.3 | 19.4 | 40.7
100+100 | 7 | 4.00 ± 0.00 | 20.4 | 27.8 | 19.4 | 32.4
100+150 | 9 | 4.61 ± 0.58 | 19.4 | 28.7 | 16.7 | 35.2
200+50 | 8 | 4.13 ± 0.08 | 17.5 | 22.5 | 19.2 | 40.8
200+100 | 8 | 4.25 ± 0.13 | 16.7 | 26.7 | 19.2 | 37.5
200+150 | 10 | 4.35 ± 0.15 | 16.7 | 30.8 | 22.5 | 30.0
400+50 | 8 | 4.88 ± 0.60 | 18.8 | 21.9 | 19.8 | 39.6
400+100 | 9 | 4.22 ± 0.21 | 18.5 | 25.0 | 23.1 | 33.3
400+150 | 5 | 4.30 ± 0.20 | 16.7 | 33.3 | 20.0 | 30.0

a AZT + isoniazid in mg/kg/day

b Group mean ± standard error

c Results of a two-way analysis of variance indicated a significant isoniazid effect (P≤0.0025) with respect to the duration of estrus.

## Other NIEHS Reports and Publications on the Toxicology of AIDS Therapeutics

National Institute of Environmental Health Sciences (NIEHS) (1997). Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide Administered by Gavage to Swiss (CD-1^®^) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 1. NIH Publication No. 97-3938. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1998). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT), Trimethoprim (TMP)/Sulfamethoxazole (SMX), and Folinic Acid Combinations Administered by Gavage to Swiss (CD-1^®^) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 2. NIH Publication No. 99-3940. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1999). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Isoniazid Combinations Administered by Gavage to Swiss (CD-1^®^) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 3. NIH Publication No. 99-3941. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Rifabutin Combinations Administered by Gavage to Swiss (CD-1^®^) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 4. NIH Publication No. 00-3948. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Subchronic Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Pyrazinamide Combinations Administered by Gavage to B6C3F_1_ Mice. NIEHS AIDS Therapeutics Toxicity Report No. 5. NIH Publication No. 00-3949. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2001). Subchronic Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Rifampicin Combinations Administered by Gavage to B6C3F_1_ Mice. NIEHS AIDS Therapeutics Toxicity Report No. 6. NIH Publication No. 01-4401. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2002). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT) and Pyrazinamide Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 7. NIH Publication No. 02-4408. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
Rao, G.N., Collins, B.J., Giles, H.D., Heath, J.E., Foley, J.F., May, R.D., and Buckley, L.A. (1996). Carcinogenicity of 2′,3′-dideoxycytidine in mice. Cancer Res. 56, 4666–4672.8840982
Rao, G.N., Lindamood, C., Heath, J.E., Farnell, D.R., and Giles, H.D. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Sanders, V.M., Elwell, M.R., Heath, J.E., Collins, B.J., Dunnick, J.K., Rao, G.N., Prejean, D., Lindamood, C., and Irwin, R.D. (1995). Induction of thymic lymphoma in mice administered the dideoxynucleoside ddC. Fundam. Appl. Toxicol. 27, 263–269.8529822
Zhuang, S.-M., Eklund, L.K., Cochran, C., Rao, G.N., Wiseman, R.W., and Soderkvist, P. (1996). Allelotype analysis of 2′,3′-dideoxycytidine- and 1,3-butadiene-induced lymphomas in B6C3F_1_ mice. Cancer Res. 56, 3338–3343.8764131