# APPENDIX B Clinical Pathology

List of Abbreviations
WBC: White blood cells
RBC: Red blood cells
HGB: Hemoglobin
HCT: Hematocrit
MCV: Mean corpuscular volume
MCH: Mean corpuscular hemoglobin
MCHC: Mean corpuscular hemoglobin concentration
LUC: Large unstained cells
ALP: Alkaline phosphatase
ALT: Alanine aminotransferase
AST: Aspartate aminotransferase
SDH: Sorbitol dehydrogenase
BILA: Total bile acids

TABLE B1 Summary of Hematology Parameters for B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations: Day 4

TABLE B2 Summary of Clinical Chemistry Parameters for B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations: Day 4