# APPENDIX A Body Weights and Organ Weights

TABLE A1 Summary Body Weight Data for B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Core Study Males

Dose^a^ | Mean Body Weight (grams) on Day of Study
Dose^a^ | -3 | 2 | 9 | 16 | 23 | 30 | 37
0+0 | 21.6 | 23.8 | 25.6 | 26.4 | 27.2 | 28.3 | 29.2
100+0 | 21.4 | 23.8 | 25.3 | 26.3 | 27.2 | 28.4 | 28.9
200+0 | 21.6 | 23.9 | 25.6 | 26.3 | 27.5 | 28.5 | 29.3
400+0 | 21.9 | 24.3 | 26.3 | 27.3 | 28.3 | 29.3 | 30.1
0+50 | 22.1 | 24.5 | 26.4 | 27.5 | 28.6 | 29.7 | 30.5
0+100 | 22.1 | 24.3 | 26.2 | 27.3 | 28.6 | 30.0 | 30.6
0+150 | 21.5 | 23.7 | 26.0 | 27.5 | 28.6 | 29.7 | 30.4
100+50 | 21.7 | 24.4 | 26.3 | 27.6 | 28.7 | 29.8 | 31.0
100+100 | 21.8 | 24.1 | 26.2 | 27.3 | 28.3 | 29.4 | 30.1
100+150 | 21.6 | 24.0 | 25.9 | 27.3 | 28.2 | 29.3 | 30.3
200+50 | 21.9 | 24.1 | 26.1 | 26.5 | 27.6 | 29.2 | 29.7
200+100 | 21.6 | 24.1 | 25.5 | 26.8 | 28.0 | 28.9 | 29.6
200+150 | 21.9 | 24.4 | 26.5 | 27.7 | 28.8 | 30.1 | 31.0
400+50 | 21.8 | 23.9 | 26.1 | 27.2 | 28.1 | 28.9 | 29.5
400+100 | 21.7 | 23.9 | 25.4 | 26.1 | 26.9 | 27.9 | 28.2
400+150 | 21.7 | 24.3 | 26.1 | 27.5 | 28.8 | 30.0 | 30.6

Dose^a^ | Mean Body Weight (grams) on Day of Study
Dose^a^ | 44 | 51 | 58 | 65 | 72 | 79 | 86
0+0 | 30.0 | 31.0 | 31.5 | 33.3 | 33.2 | 33.5 | 34.2
100+0 | 30.1 | 31.2 | 32.1 | 33.4 | 33.6 | 33.9 | 34.3
200+0 | 30.7 | 31.6 | 32.6 | 34.1 | 34.0 | 34.8 | 35.5
400+0 | 31.1 | 32.2 | 32.5 | 33.6 | 34.3 | 34.7 | 35.5
0+50 | 31.5 | 32.8 | 33.5 | 34.8 | 35.4 | 35.8 | 36.3
0+100 | 31.8 | 32.6 | 33.6 | 34.9 | 35.0 | 35.1 | 35.7
0+150 | 31.4 | 32.0 | 33.0 | 34.2 | 34.0 | 34.8 | 35.6
100+50 | 32.3 | 33.7 | 34.8 | 36.3 | 37.1 | 37.2 | 38.2
100+100 | 31.2 | 32.1 | 32.7 | 34.3 | 34.6 | 35.2 | 35.5
100+150 | 31.3 | 31.9 | 32.7 | 34.0 | 34.0 | 34.6 | 35.6
200+50 | 31.0 | 32.2 | 32.9 | 34.4 | 34.7 | 35.4 | 36.2
200+100 | 30.1 | 31.6 | 32.1 | 33.6 | 33.6 | 34.4 | 35.0
200+150 | 31.5 | 32.4 | 32.9 | 34.3 | 34.4 | 34.7 | 35.5
400+50 | 30.2 | 31.4 | 32.2 | 33.7 | 33.6 | 34.0 | 34.5
400+100 | 29.0 | 30.2 | 31.0 | 32.2 | 32.6 | 32.5 | 33.4
400+150 | 31.2 | 32.2 | 32.8 | 34.3 | 34.8 | 35.5 | 36.2

a AZT + isoniazid in mg/kg/day

Core Study Females

Dose^a^ | Mean Body Weight (grams) on Day of Study
Dose^a^ | -3 | 4 | 11 | 18 | 25 | 32 | 39
0+0 | 17.9 | 18.8 | 19.9 | 21.5 | 22.8 | 22.3 | 23.8
100+0 | 17.9 | 18.4 | 20.5 | 21.7 | 22.5 | 21.8 | 23.0
200+0 | 18.1 | 19.0 | 20.6 | 22.0 | 22.7 | 23.9 | 24.2
400+0 | 17.9 | 18.1 | 20.5 | 21.5 | 22.7 | 23.5 | 24.0
0+50 | 17.6 | 18.6 | 20.5 | 21.3 | 22.8 | 23.8 | 24.5
0+100 | 18.0 | 19.5 | 20.9 | 22.0 | 23.4 | 24.0 | 25.0
0+150 | 17.6 | 19.1 | 20.5 | 21.6 | 22.8 | 23.6 | 24.5
100+50 | 17.7 | 18.2 | 20.3 | 21.1 | 23.3 | 23.7 | 24.3
100+100 | 17.7 | 18.6 | 20.5 | 21.0 | 22.8 | 23.5 | 23.8
100+150 | 17.6 | 19.0 | 20.2 | 21.2 | 22.3 | 22.6 | 24.0
200+50 | 18.0 | 19.3 | 20.5 | 21.7 | 22.7 | 23.2 | 23.6
200+100 | 17.8 | 18.6 | 19.5 | 21.6 | 22.8 | 23.3 | 22.4
200+150 | 17.3 | 18.9 | 20.2 | 20.2 | 22.1 | 22.5 | 23.3
400+50 | 18.0 | 18.8 | 20.3 | 21.4 | 21.9 | 23.2 | 23.9
400+100 | 17.6 | 18.8 | 20.8 | 21.9 | 23.1 | 23.5 | 24.6
400+150 | 17.8 | 19.4 | 20.5 | 21.0 | 22.2 | 22.5 | 21.2

Dose^a^ | Mean Body Weight (grams) on Day of Study
Dose^a^ | 46 | 53 | 60 | 67 | 74 | 81 | 88
0+0 | 25.2 | 25.9 | 27.5 | 28.3 | 28.3 | 27.8 | 27.9
100+0 | 24.7 | 25.1 | 26.3 | 26.4 | 27.2 | 27.0 | 26.9
200+0 | 25.0 | 26.4 | 26.5 | 27.9 | 27.8 | 27.8 | 27.7
400+0 | 25.1 | 25.4 | 25.5 | 26.6 | 27.2 | 25.9 | 26.5
0+50 | 25.1 | 26.0 | 27.1 | 29.2 | 28.2 | 28.8 | 29.9
0+100 | 25.8 | 27.0 | 27.8 | 28.2 | 29.4 | 29.2 | 29.9
0+150 | 24.5 | 25.6 | 26.5 | 27.5 | 27.2 | 27.7 | 27.2
100+50 | 25.2 | 26.4 | 26.3 | 28.0 | 28.5 | 28.8 | 28.7
100+100 | 23.9 | 25.5 | 25.9 | 26.5 | 27.2 | 27.8 | 27.4
100+150 | 24.4 | 24.5 | 25.4 | 26.3 | 26.5 | 26.4 | 25.4
200+50 | 24.7 | 25.5 | 26.8 | 28.1 | 28.0 | 28.2 | 28.7
200+100 | 24.7 | 25.8 | 25.8 | 28.1 | 28.1 | 28.2 | 28.6
200+150 | 23.6 | 24.5 | 24.8 | 26.2 | 26.0 | 26.0 | 26.3
400+50 | 24.6 | 25.5 | 24.0 | 27.2 | 27.4 | 28.1 | 28.3
400+100 | 25.2 | 25.4 | 26.6 | 26.8 | 28.5 | 28.6 | 28.3
400+150 | 25.7 | 26.1 | 26.4 | 28.2 | 27.6 | 26.4 | 27.8

a AZT + isoniazid in mg/kg/day

TABLE A2 Summary Organ Weight Data for B6C3F_1_ Mice from the 13-Week Toxicity Study of AZT and Isoniazid Combinations

Core-Study Males

Dose^a^ | Mean Body Weight (g) | n | Organ Weight (g)^b^ | Organ to Body Ratio × 1,000^b^ | Organ Weight (g)^b^ | Organ to Body Ratio × 1,000^b^
| | | Liver | | Right Kidney
0+0 | 34.62 | 10 | 1.5256 ± 0.1503(—)^c^ | 43.9 ± 4.4(—)^c^ | 0.2830 ± 0.0250(—) | 8.2 ± 0.7(—)
100+0 | 34.93 | 9 | 1.5200 ± 0.1295(−0.4) | 43.7 ± 3.9(−0.4) | 0.2900 ± 0.0218(+2.5) | 8.4 ± 0.9(+1.4)
200+0 | 35.98 | 10 | 1.5250 ± 0.1606(+0.0) | 42.5 ± 2.5(−3.2) | 0.2760 ± 0.0237(−2.5) | 7.7 ± 0.7(−6.5)
400+0 | 36.60^c^ | 10 | 1.5970 ± 0.1210(+4.7) | 44.0 ± 2.8(+0.3)^c^ | 0.2880 ± 0.0274(+1.8) | 8.0 ± 0.7(−2.7)^c^
0+50 | 37.36 | 10 | 1.6530 ± 0.1587(+8.4) | 44.2 ± 3.3(+0.8) | 0.2990 ± 0.0273(+5.7) | 8.0 ± 0.6(−3.0)
100+50 | 38.86^*^,^c^ | 10 | 1.6890 ± 0.1368(+10.7)^*^ | 43.2 ± 3.2(−1.5)^c^ | 0.2890 ± 0.0223(+2.1) | 7.4 ± 0.7(−9.7)^*^,^c^
200+50 | 37.09 | 10 | 1.5400 ± 0.1372(+0.9)^c^ | 42.2 ± 1.7(−3.7)^c^ | 0.2800 ± 0.0302(−1.1) | 7.5 ± 0.5(−8.5)^*^
400+50 | 35.49 | 10 | 1.5610 ± 0.1859(+2.3) | 44.0 ± 2.6(+0.2) | 0.2778 ± 0.0249(−1.8)^c^ | 8.0 ± 0.7(−2.5)^c^
0+100 | 36.38 | 10 | 1.5620 ± 0.1586(+2.4) | 43.0 ± 2.3(−1.9) | 0.2770 ± 0.0245(−2.1) | 7.6 ± 0.5(−7.3)^*^
100+100 | 35.91 | 10 | 1.5710 ± 0.0989(+3.0) | 43.8 ± 2.4(−0.1) | 0.2810 ± 0.0233(−0.7) | 7.8 ± 0.5(−5.0)
200+100 | 35.15 | 10 | 1.5430 ± 0.1345(+1.1) | 44.0 ± 2.8(+0.2) | 0.2670 ± 0.0170(−5.7) | 7.6 ± 0.7(−7.5)^*^
400+100 | 33.80 | 10 | 1.5689 ± 0.1769(+2.8)^c^ | 45.4 ± 3.4(+3.5)^c^ | 0.2610 ± 0.0300(−7.8)^*^ | 7.7 ± 0.5(−6.4)
0+150 | 34.15 | 10 | 1.6070 ± 0.1541(+5.3) | 47.6 ± 7.3(+8.5)^*^ | 0.2870 ± 0.0177(+1.4) | 8.5 ± 1.2(+3.3)
100+150 | 35.68 | 10 | 1.6170 ± 0.1948(+6.0) | 45.2 ± 2.4(+3.1) | 0.2770 ± 0.0221(−2.1) | 7.8 ± 0.4(−5.7)
200+150 | 35.10 | 10 | 1.6040 ± 0.1841(+5.1) | 45.6 ± 3.3(+4.0) | 0.2789 ± 0.0293(−1.5)^c^ | 8.0 ± 0.6(−2.9)^c^
400+150 | 36.52 | 10 | 1.6640 ± 0.1200(+9.1) | 45.6 ± 2.4(+4.0) | 0.2850 ± 0.0201(+0.7) | 7.8 ± 0.6(−5.2)
| | | Thymus | | Heart
0+0 | 34.62 | 10 | 0.0385 ± 0.0044(—) | 1.1 ± 0.2(—) | 0.1490 ± 0.0110(—) | 4.4 ± 0.6(—)
100+0 | 34.93 | 9 | 0.0350 ± 0.0046(−9.1) | 1.0 ± 0.2(−11.0) | 0.1563 ± 0.0130(+4.9)^d^ | 4.5 ± 0.3(+3.4)^d^
200+0 | 35.98 | 10 | 0.0333 ± 0.0059(−13.5)^*^ | 0.9 ± 0.1(−19.0)^*^ | 0.1510 ± 0.0166(+1.3) | 4.2 ± 0.4(−3.5)
400+0 | 36.60^c^ | 10 | 0.0373 ± 0.0074(−3.1) | 1.0 ± 0.2(−7.9)^c^ | 0.1450 ± 0.0118(−2.7) | 4.0 ± 0.2(−9.0)^*^,^c^
0+50 | 37.36 | 10 | 0.0361 ± 0.0061(−6.2)^c^ | 1.0 ± 0.1(−15.1)^*^,^c^ | 0.1550 ± 0.0108(+4.0) | 4.2 ± 0.2(−4.9)
100+50 | 38.86^*^,^c^ | 10 | 0.0349 ± 0.0053(−9.3) | 0.9 ± 0.1(−21.5)^*^,^c^ | 0.1580 ± 0.0140(+6.0) | 4.1 ± 0.5(−5.8)^c^
200+50 | 37.09 | 10 | 0.0395 ± 0.0071(+2.6) | 1.1 ± 0.2(−6.4) | 0.1510 ± 0.0145(+1.3) | 4.1 ± 0.3(−6.7)
400+50 | 35.49 | 10 | 0.0316 ± 0.0048(−18.0)^*^,^c^ | 0.9 ± 0.1(−20.7)^*^,^c^ | 0.1490 ± 0.0120(+0.0) | 4.2 ± 0.4(−3.4)
0+100 | 36.38 | 10 | 0.0369 ± 0.0043(−4.2)^c^ | 1.0 ± 0.1(−9.0)^c^ | 0.1450 ± 0.0127(−2.7) | 4.0 ± 0.2(−8.4)^*^
100+100 | 35.91 | 10 | 0.0361 ± 0.0017(−6.2) | 1.0 ± 0.1(−11.3) | 0.1500 ± 0.0105(+0.7) | 4.2 ± 0.3(−4.2)
200+100 | 35.15 | 10 | 0.0333 ± 0.0047(−13.5)^*^ | 1.0 ± 0.1(−16.3)^*^ | 0.1480 ± 0.0103(−0.7) | 4.2 ± 0.3(−3.3)
400+100 | 33.80 | 10 | 0.0355 ± 0.0074(−7.8) | 1.0 ± 0.2(−7.8) | 0.1420 ± 0.0140(−4.7) | 4.2 ± 0.3(−3.6)
0+150 | 34.15 | 10 | 0.0366 ± 0.0040(−4.9) | 1.1 ± 0.2(−4.4) | 0.1510 ± 0.0120(+1.3) | 4.5 ± 1.8(+2.9)
100+150 | 35.68 | 10 | 0.0342 ± 0.0046(−11.2) | 1.0 ± 0.1(−15.7)^*^ | 0.1540 ± 0.0151(+3.4) | 4.3 ± 0.3(−1.0)
200+150 | 35.10 | 10 | 0.0366 ± 0.0061(−4.9) | 1.0 ± 0.2(−7.9) | 0.1510 ± 0.0099(+1.3) | 4.3 ± 0.3(−1.2)
400+150 | 36.52 | 10 | 0.0360 ± 0.0033(−6.5) | 1.0 ± 0.1(−13.0)^*^ | 0.1590 ± 0.0145(+6.7) | 4.4 ± 0.3(−0.2)
| | | Lungs | | Right Testicle
0+0 | 34.62 | 10 | 0.2150 ± 0.0519(—) | 6.3 ± 1.4(—) | 0.1116 ± 0.0151(—)^c^ | 3.2 ± 0.4(—)^c^
100+0 | 34.93 | 9 | 0.2156 ± 0.0388(+0.3) | 6.2 ± 1.0(−1.1) | 0.1151 ± 0.0072(+3.2) | 3.3 ± 0.3(+4.3)
200+0 | 35.98 | 10 | 0.2189 ± 0.0470(+1.8)^c^ | 6.2 ± 1.4(−1.2)^c^ | 0.1075 ± 0.0131(−3.6) | 3.0 ± 0.4(−5.4)
400+0 | 36.60^c^ | 10 | 0.1989 ± 0.0237(−7.5)^c^ | 5.5 ± 0.6(−12.4)^d^ | 0.1130 ± 0.0121(+1.3) | 3.1 ± 0.3(−1.4)^c^
0+50 | 37.36 | 10 | 0.2210 ± 0.0479(+2.8) | 5.9 ± 1.3(−5.3) | 0.1184 ± 0.0099(+6.1) | 3.2 ± 0.2(−0.2)
100+50 | 38.86^*^,^c^ | 10 | 0.2156 ± 0.0461(+0.3)^c^ | 5.6 ± 1.5(−10.2)^c^ | 0.1215 ± 0.0130(+8.9)^*^ | 3.1 ± 0.4(−1.3)^c^
200+50 | 37.09 | 10 | 0.2144 ± 0.0279(−0.3)^c^ | 5.7 ± 0.7(−8.6)^c^ | 0.1087 ± 0.0148(−2.6) | 2.9 ± 0.3(−7.8)
400+50 | 35.49 | 10 | 0.1850 ± 0.0107(−14.0)^d^ | 5.4 ± 0.4(−14.0)^d^ | 0.1092 ± 0.0094(−2.1)^c^ | 3.1 ± 0.2(−2.8)^c^
0+100 | 36.38 | 10 | 0.2220 ± 0.0413(+3.3) | 6.2 ± 1.3(−1.5) | 0.1147 ± 0.0047(+2.8) | 3.2 ± 0.3(+0.2)
100+100 | 35.91 | 10 | 0.2180 ± 0.0498(+1.4) | 6.1 ± 1.4(−2.7) | 0.1177 ± 0.0069(+5.5) | 3.3 ± 0.2(+3.5)
200+100 | 35.15 | 10 | 0.2020 ± 0.0294(−6.0) | 5.8 ± 0.9(−7.8) | 0.1133 ± 0.0054(+1.6) | 3.2 ± 0.2(+1.9)
400+100 | 33.80 | 10 | 0.2078 ± 0.0549(−3.4)^c^ | 6.0 ± 1.3(−4.2)^c^ | 0.1052 ± 0.0120(−5.7) | 3.1 ± 0.4(−1.5)
0+150 | 34.15 | 10 | 0.2170 ± 0.0359(+0.9) | 6.6 ± 2.1(+5.0) | 0.1143 ± 0.0092(+2.5) | 3.4 ± 0.5(+6.8)
100+150 | 35.68 | 10 | 0.2144 ± 0.02961(−0.3)^c^ | 5.9 ± 0.6(−5.2)^c^ | 0.1152 ± 0.0062(+3.3)^c^ | 3.2 ± 0.4(+0.8)^c^
200+150 | 35.10 | 10 | 0.2122 ± 0.0342(−1.3)^c^ | 6.0 ± 0.9(−3.9)^c^ | 0.1108 ± 0.0136(−0.7) | 3.2 ± 0.3(−0.7)
400+150 | 36.52 | 10 | 0.2140 ± 0.0259(−0.5) | 5.9 ± 1.0(−5.6) | 0.1106 ± 0.0074(−0.9) | 3.0 ± 0.2(−4.3)

a AZT + isoniazid in mg/kg/day

b Mean value ± SD (% difference from control)

c n=9

d n=8

* P≤0.05 by Student’s f-test

Core-Study Females

Dose^a^ | Mean Body Weight (g) | n | Organ Weight (g)^b^ | Organ to Body Ratio × 1,000^b^ | Organ Weight (g)^b^ | Organ to Body Ratio × 1,000^b^
| | | Liver | | Right Kidney
0+0 | 28.18 | 10 | 1.1756 ± 0.1033(—)^c^ | 44.0 ± 7.4(—)^c^ | 0.1750 ± 0.0151(—) | 6.3 ± 1.1(—)
100+0 | 27.39^c^ | 10 | 1.1550 ± 0.0987(−1.7) | 42.2 ± 1.9(−4.3)^c^ | 0.1760 ± 0.0107(+0.6) | 6.4 ± 0.6(+1.6)^c^
200+0 | 27.02 | 10 | 1.1350 ± 0.0799(−3.4) | 42.1 ± 3.2(−4.4) | 0.1730 ± 0.0134(−1.0) | 6.4 ± 0.3(+1.2)
400+0 | 27.26^c^ | 10 | 1.1322 ± 0.1059(−3.7)^c^ | 41.6 ± 2.5(−5.6)^c^ | 0.1720 ± 0.0132(−1.7) | 6.3 ± 0.5(+0.0)^c^
0+50 | 29.39 | 10 | 1.2510 ± 0.0936(+6.4) | 43.3 ± 7.5(−1.6) | 0.1860 ± 0.0143(+6.3) | 6.4 ± 1.0(+1.5)
100+50 | 29.71^d^ | 9 | 1.1756 ± 0.0814(+0.0) | 40.0 ± 3.8(−9.2)^d^ | 0.1778 ± 0.0097(+1.6) | 6.0 ± 0.8(−4.6)^d^
200+50 | 29.58^c^ | 10 | 1.1890 ± 0.0999(+1.1) | 40.3 ± 2.8(−8.6)^c^ | 0.1730 ± 0.0157(−1.1) | 6.0 ± 0.6(−6.0)^c^
400+50 | 28.94 | 8 | 1.1417 ± 0.1329(−2.9)^e^ | 41.0 ± 3.7(−6.9)^e^ | 0.1743 ± 0.0199(−0.4)^f^ | 6.1 ± 0.8(−4.0)^f^
0+100 | 30.60 | 10 | 1.2300 ± 0.1001(+4.6)^c^ | 41.5 ± 2.4(−5.7)^c^ | 0.1860 ± 0.0158(+6.3) | 6.1 ± 0.7(−3.2)
100+100 | 27.98 | 9 | 1.1633 ± 0.1136(−1.0) | 41.7 ± 2.5(−5.3) | 0.1789 ± 0.0136(+2.2) | 6.4 ± 0.5(+1.5)
200+100 | 28.50 | 10 | 1.1820 ± 0.1324(+0.5) | 41.5 ± 4.4(−5.7) | 0.1780 ± 0.0162(+1.7) | 6.3 ± 0.5(−1.3)
400+100 | 28.10^d^ | 9 | 1.2244 ± 0.1152(+4.2) | 43.6 ± 7.8(−0.9)^d^ | 0.1867 ± 0.0087(+6.7) | 6.8 ± 1.2(+7.3)^d^
0+150 | 26.78^e^ | 7 | 1.1817 ± 0.1344(+0.5)^e^ | 44.0 ± 3.2(+0.0)^e^ | 0.1814 ± 0.0135(+3.7) | 6.7 ± 0.5(+6.2)^e^
100+150 | 26.87 | 9 | 1.1633 ± 0.1183(−1.0) | 43.4 ± 3.6(−1.4) | 0.1833 ± 0.0173(+4.8) | 6.9 ± 0.8(+8.4)
200+150 | 25.85 | 10 | 1.1113 ± 0.0442(−5.5)^d^ | 41.8 ± 2.1(−5.0)^d^ | 0.1710 ± 0.0208(−2.3) | 6.6 ± 0.5(+4.4)
400+150 | 27.90 | 5 | 1.1740 ± 0.0483(−0.1) | 42.1 ± 2.3(−4.4) | 0.1840 ± 0.0055(+5.1) | 6.6 ± 0.3(+4.2)
| | | Thymus | | Heart
0+0 | 28.18 | 10 | 0.0446 ± 0.0042(—) | 1.6 ± 0.3(—) | 0.1210 ± 0.0099(—) | 4.4 ± 0.7(—)
100+0 | 27.39^c^ | 10 | 0.0382 ± 0.0071(−14.3)^*^ | 1.4 ± 0.2(−14.5)^c^ | 0.1210 ± 0.0099(+0.0) | 4.4 ± 0.4(+0.4)^c^
200+0 | 27.02 | 10 | 0.0411 ± 0.0070(−7.8) | 1.5 ± 0.3(−5.0) | 0.1220 ± 0.0114(+0.8) | 4.5 ± 0.2(+3.1)
400+0 | 27.26^c^ | 10 | 0.0418 ± 0.0053(−6.3) | 1.5 ± 0.2(−5.6)^c^ | 0.1240 ± 0.0084(+2.5) | 4.6 ± 0.4(+5.7)^c^
0+50 | 29.39 | 10 | 0.0426 ± 0.0067(−4.4)^d^ | 1.5 ± 0.4(−7.8)^d^ | 0.1280 ± 0.0114(+5.8) | 4.4 ± 0.7(+1.0)
100+50 | 29.71^d^ | 9 | 0.0411 ± 0.0044(−7.8) | 1.4 ± 0.3(−12.8)^d^ | 0.1233 ± 0.0100(+1.9) | 4.2 ± 0.6(−4.9)^d^
200+50 | 29.58^c^ | 10 | 0.0400 ± 0.0062(−10.3)^c^ | 1.3 ± 0.2(−18.2)^*^,^d^ | 0.1190 ± 0.0166(−1.7) | 4.0 ± 0.6(−8.7)^c^
400+50 | 28.94 | 8 | 0.0358 ± 0.0086(−19.8)^*^ | 1.3 ± 0.3(−22.1)^*^ | 0.1175 ± 0.0139(−2.9) | 4.1 ± 0.3(−6.7)
0+100 | 30.60 | 10 | 0.0456 ± 0.0081(+2.2) | 1.5 ± 0.3(−6.9) | 0.1240 ± 0.0126(+2.5) | 4.1 ± 0.6(−6.3)
100+100 | 27.98 | 9 | 0.0424 ± 0.0066(−4.8) | 1.5 ± 0.2(−5.9) | 0.1256 ± 0.0133(+3.8) | 4.5 ± 0.4(+2.8)
200+100 | 28.50 | 10 | 0.0413 ± 0.0089(−7.4) | 1.5 ± 0.3(−10.0) | 0.1240 ± 0.0097(+2.5) | 4.4 ± 0.4(−0.4)
400+100 | 28.10^d^ | 9 | 0.0402 ± 0.0041(−9.8) | 1.5 ± 0.3(−7.8)^d^ | 0.1244 ± 0.0113(+2.8) | 4.5 ± 0.6(+2.4)^d^
0+150 | 26.78^e^ | 7 | 0.0407 ± 0.0060(−8.7) | 1.5 ± 0.1(−9.8)^e^ | 0.1186 ± 0.0090(−2.0) | 4.5 ± 0.3(+2.5)^e^
100+150 | 26.87 | 9 | 0.0396 ± 0.0036(−11.3) | 1.5 ± 0.2(−8.2) | 0.1144 ± 0.0053(−5.4) | 4.3 ± 0.3(−2.1)
200+150 | 25.85 | 10 | 0.0386 ± 0.0087(−13.5)^*^ | 1.5 ± 0.3(−7.0) | 0.1122 ± 0.0083(−7.3)^c^ | 4.4 ± 0.3(+0.0)^c^
400+150 | 27.90 | 5 | 0.0396 ± 0.0061(−11.2) | 1.4 ± 0.2(−11.9) | 0.1300 ± 0.0100(+7.4) | 4.7 ± 0.4(+6.4)
| | | Lungs
0+0 | 28.18 | 10 | 0.1850 ± 0.0212(—) | 6.6 ± 0.9(—)
100+0 | 27.39^c^ | 10 | 0.1790 ± 0.0223(−3.2) | 6.5 ± 0.8(−2.0)^c^
200+0 | 27.02 | 10 | 0.1890 ± 0.0269(+2.2) | 7.0 ± 1.0(+5.6)
400+0 | 27.26^c^ | 10 | 0.1790 ± 0.0191(−3.2) | 6.5 ± 0.7(−2.3)^c^
0+50 | 29.39 | 10 | 0.1711 ± 0.0154(−7.5)^c^ | 6.0 ± 1.3(−9.9)^c^
100+50 | 29.71^d^ | 9 | 0.1900 ± 0.0287(+2.7) | 6.4 ± 1.4(−3.4)^d^
200+50 | 29.58^c^ | 10 | 0.1850 ± 0.0264(+0.0) | 6.2 ± 0.8(−6.7)^c^
400+50 | 28.94 | 8 | 0.1750 ± 0.0193(−5.4) | 6.2 ± 1.3(−7.0)
0+100 | 30.60 | 10 | 0.1820 ± 0.0175(−1.6) | 6.0 ± 0.7(−9.6)
100+100 | 27.98 | 9 | 0.1700 ± 0.0158(−8.1) | 6.1 ± 0.7(−7.8)
200+100 | 28.50 | 10 | 0.1730 ± 0.0250(−6.5) | 6.1 ± 0.9(−8.4)
400+100 | 28.10^d^ | 9 | 0.1800 ± 0.0300(−2.7) | 6.4 ± 1.2(−3.9)^d^
0+150 | 26.78^e^ | 7 | 0.1643 ± 0.0172(−11.2) | 6.2 ± 0.7(−6.1)^e^
100+150 | 26.87 | 9 | 0.1733 ± 0.01941(−6.3) | 6.5 ± 0.7(−2.4)
200+150 | 25.85 | 10 | 0.1690 ± 0.0242(−8.6) | 6.5 ± 0.6(−1.7)
400+150 | 27.90 | 5 | 0.1760 ± 0.0219(−4.9) | 6.3 ± 0.8(−4.9)

a AZT + isoniazid in mg/kg/day

b Mean value ± standard deviation (% difference from control)

c n=9

d n=8

e n=6

f n=7

* P≤0.05 by Student’s f-test