# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Barnes, P.F., Bloch, A.B., Davidson, P.T., and Snider, D.E. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Eng. J. Med.. 324, 1644–1650.
Baron, D.N., and Bell, J.L. (1974). Serum enzyme changes in patients receiving antituberculosis therapy with rifampin or p-aminosalicylic acid, + isoniazid and streptomycin. Tubercle 55, 115–120.4620296
Barry, C.E. (1997). New horizons in the treatment of tuberculosis. Biochem. Pharm. 54(11), 1165–1172.9416967
Bederka, J.P. Jr., Davitiyananda, D., Moses, M.L., and Amad, N. (1975). Drug-biomolecule interactions: Drug toxicity and vitamin coenzyme depletion. J. Pharm. Sci. 64, 528–534.239196
Bick, R.L. (1993). Hematology Clinical and Laboratory Practice, pp. 185–201. Mosby Press, St. Louis.
Blanchard, J.S. (1996). Molecular mechanisms of drug resistance in Mycobacterium tuberculosis. Annu. Rev. Biochem. 65, 215–239.8811179
Centers for Disease Control (CDC) (1987). Diagnosis and management of mycobacterial infection and disease in persons with human immunodeficiency virus infection. Ann. Intern. Med. 106, 254–256.3800186
Centers for Disease Control (CDC) (1998a). Prevention and treatment of tuberculosis among patients infected with human immunodeficiency virus: Principles of therapy and revised recommendations. MMWR 47(RR-20), 1–51.
Centers for Disease Control (CDC) (1998b). Guidelines for the use of antiretroviral agents in HIV-infected adults and adolescents. MMWR 47(RR-5), 39–82.
Chow, R.F., Sutton, P.A., and Hamburger, A.W. (1991). Sensitivity of erythroid progenitor colonies to erythropoietin in azidothymidine treated immunodeficient mice. Brit. J. Haematol. 77, 139–144.2004015
Coffin J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Cretton, E.M., Xie, M.Y., Bevan, R.J., Goudgaon, N.M., Schinazi, R.F., and Sommadossi, J.P. (1991). Catabolism of 3′-azido-3′-deoxythymidine in hepatocytes and liver microsomes, with evidence of formation of 3′-amino-3′-deoxythymidine, a highly toxic catabolite for human bone marrow cells. Mol. Pharmacol. 39, 258–266.1996084
Dixon, W.J., and Massey, F.J., Jr. (1951). Introduction to Statistical Analysis, 1st ed., pp. 145–147. McGraw-Hill Book Company, New York.
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1096–1121.
Durand, F., Jebrak, G., Pessayre, D., Fournier, M., and Bernuau, J. (1996). Hepatotoxicity of antitubercular treatments. Drug Safety 6, 394–405.
East and Central African/British Medical Research Council Fifth Collaborative Study (1986). Controlled clinical trial of 4 short-course regimens of chemotherapy (three 6-month and one 8-month) for pulmonary tuberculosis: final report. Tubercle 67, 5–15.3521015
Fahrmeir, L., and Tutz, G. (1994). Multivariate statistical modeling based on generalized linear models, p. 73. Springer-Verlag, New York.
Freireich, E.J., Gehan, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Cancer Chemother. Rep. 50, 219–244.4957125
Gogu, S.R., Beckman, B.S., Wilson, R.B., and Agrawal, K.C. (1995). Inhibitory effects of zidovudine in erythroid progenitor cells: Reversal with a combination of erythropoietin and interleukin-3. Biochem. Pharmacol. 50, 413–419.7646543
Goldschmidt, R.H., and Dong, B.J. (1992). Current Report - HIV. Treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. New Eng. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Grosset, J., Truffot-Pernot, C., Lacroix, C., and Ji, B. (1992). Antagonism between isoniazid and the combination pyrazinamide-rifampin against tuberculosis infection in mice. Antimicrob. Agents Chemother. 36, 545–551.1622163
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Harris, M.W., Chapin, R.E., Lockhart, A.C., and Jokinen, M.P. (1992) Assessment of short-term reproductive and developmental toxicity screen. Fundam. Appl. Toxicol. 19, 186–196.1516774
Humma, L.M. (1996). Prevention and treatment of drug-resistant tuberculosis. Am. J. Health Syst. Pharm. 53, 2291–2298.8893067
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18, 5–13.2464649
Jonckheere, A.R. (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Mandell, G.L., and Sande, M.A. (1990). Drugs used in the chemotherapy of tuberculosis and leprosy. In Goodman and Gilman=s The Pharmacological Basis of Therapeutics, 8th ed. (A.G. Gilman, R.W. Rall, A.S. Niles, and P. Taylor, Eds.) pp. 1146–1164. Pergamon Press, New York.
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biologic and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Vande Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. New Eng. J. Med. 305, 1431–1438.6975437
Morrisey, R.E., Harris, M.W., and Schwetz, B.A. (1989). Developmental toxicity screen. Results of rat studies with diethylhexyl phthalate and ethylene glycol monomethyl ether. Teratog. Carcinog. Mutagen. 9, 119–129.2568021
National Institute of Environmental Health Sciences (NIEHS) (1997). Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide Administered by Gavage to Swiss (CD-1^7^) mice. NIEHS AIDS Therapeutics Toxicity Report No. 1. NIH Publication No. 97–3938. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1999). Reproductive, Developmental, and General Toxicity Studies of 3´-Azido-3´-deoxythymidine (AZT)/Isoniazid Combinations Administered by Gavage to Swiss (CD-1^7^) mice. NIEHS AIDS Therapeutics Toxicity Report No. 3. NIH Publication No. 99-3941. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Subchronic Toxicity Studies of 3´-Azido-3´-deoxythymidine (AZT)/Pyrazinamide Combinations Administered by Gavage to B6C3F_1_ mice. NIEHS AIDS Therapeutics Toxicity Report No. 5. NIH Publication No. 00-3949. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/_-Interferon A/D in B6C3F_1_ mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. Research Triangle Park, N.C.
Nolan, C.M. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Am. J. Infect. Control 20, 30–34.1554145
Physicians’ Desk Reference (PDR) (1999). 53rd ed., pp. 1172–1174 and 1202–1207. Medical Economics Data, Medical Economics Company, Inc., Montvale, NJ.
Ramakrishnan, C.V., Janardhanam, B., Krishnamurthy, D.V., Stott, H., Subbammal, S., and Tripathy, S.P. (1968). Toxicity of pyrazinamide administered once weekly in high dosage in tuberculosis patients. Bull. W.H.O. 39, 775–779.5306313
Rao, G.N., Lindamood, C., Heath, J.E., Farnell, D.R., and Giles, H.D. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Registry of Toxic Effects of Chemical Substances (RTECS) (1983). 1981–1982 Edition, Vol. 3 (P-Z), p. 393. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH.
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infect. Dis. Clin. North Am. 2, 397–497.2462584
Richman, D.D., Fischl, M.A., Grieco, M.H., Gottlieb, M.S., Volberding, P.A., Laskin, O.L., Leedom, J.M., Groopman, J.E., Mildvan, D., Hirsch, M.S., Jackson, G.G., Durack, D.T., Phil, D., Nusinoff-Lehrman, S., and the AZT Collaborative Working Group. (1987). The toxicity of azidothymidine (AZT) in the treatment of patients with AIDS and AIDS-related complex. New Eng. J. Med. 4, 192–197.
Roman, I.C., and Georgian, L. (1977). Cytogenetic effects of some anti-tuberculosis drugs in vitro. Mutat. Res. 48, 215–224.876269
Scheffe, H. (1953). A method for judging all contrasts in the analysis of variance. Biometrika 40, 87–104.
Shirley, E. (1977). A non-parametric equivalent of Williams=test for contrasting increasing dose levels of a treatment. Biometrics 33, 386–389.884197
Siegel, S. (1956). Nonparametric Statistics for the Behavioral Sciences, pp. 96–104. McGraw-Hill Book Company, Inc., New York.
Siegle, F.P., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. New Eng. J. Med. 305, 1439–1444.6272110
Snedecor, G.W., and Cochran, W.G., Eds. (1967a). Test for a linear trend in proportions. In Statistical Methods, 6th ed., pp. 246–248. Iowa State University Press, Ames, IA.
Snedecor, G.W., and Cochran, W.G., Eds. (1967b). Analysis of variance. In Statistical Methods, 6th ed., pp. 258–275. Iowa State University Press, Ames, IA.
Snower, D.P., and Weil, S.C. (1993). Changing etiology of macrocytosis. Am. J. Clin. Pathol. 99(1), 57–60.8422018
Sokal, R.R., and Rohlf, F.J. (1969a). Bartlett=s test of homogeneity of variances. In Biometry, pp. 370–371. W.H. Freeman and Co., San Francisco.
Sokal, R.R., and Rohlf, F.J. (1969b). Kruskal-Wallis Test. In Biometry, pp. 388–389. W.H. Freeman and Co., San Francisco.
Thompson M.B., Dunnick, J.K., Sutphin, M.E., Giles, H.D., Irwin, R.D., and Prejean J.D. (1991). Hematologic toxicity of AZT and ddC administered as single agents and in combination to rats and mice. Fundam. Appl. Toxicol. 17, 159–176.1655546
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F_1_ mice. Drug Metab. Dispos. 21, 189–193.8095218
Vince, R., Hua, M., Brownell, J., Daluge, S., Fangchem, L., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against Human Immunodeficiency Virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Weiner, I.M., and Tinker, J.P. (1972). Pharmacology of pyrazinamide: Metabolic and renal function studies related to the mechanism of drug-induced urate retention. J. Pharmacol. Exp. Ther. 180, 411–434.4622054
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics. 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics. 28, 519–531.5037867
Zitkova, L., Stastna, J., Tousek, J., and Viklicky, J. (1983). Toxicity of morphaxinamide compared with pyrazinamide. Czech. Med. 6, 140–151.6416791