# Peer Review

The draft report on the reproductive, developmental, and general toxicity study of 3′-azido-3′-deoxythymidine (AZT) and pyrazinamide combinations was evaluated by the following reviewers. These reviewers served as independent scientists, not as representatives of any institution, company, or government agency. In this capacity, reviewers determine if the design and conditions of the study are appropriate and ensure that this reproductive, developmental, and general toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- E. Sidney Hunter III, Ph.D.
  U.S. Environmental Protection Agency
  Health Effects Research Laboratory
  Research Triangle Park, NC
- Jay Gandy, Ph.D.
  University of Arkansas for Medical Sciences
  Department of Pharmacology and Toxicology
  Little Rock, AR