# Discussion and Conclusions

A reproductive, developmental, and general toxicity study was conducted in Swiss CD-1® mice treated with AZT alone (200 or 400 mg/kg per day), pyrazinamide alone (300, 1,500, or 3,000 mg/kg per day), or combinations of AZT and pyrazinamide. The test articles were administered by oral gavage for approximately 20 days to male mice, approximately 30 days to female mice (female-A), and approximately 10 days to female mice (female-B).

Measurable evidence of hematopoietic toxicity occurred in male and female mice treated with AZT alone. The most significant alteration in male and female-A mice treated with AZT alone consisted of a mild anemia accompanied by elevated MCV and MCH values. The anemia was related to dose and duration of treatment as the severity was greatest in female-A mice treated for approximately 30 days when compared to the male mice treated for approximately 20 days. Hematological alterations in female-B mice treated with AZT alone for approximately 10 days were limited to mild elevations in MCV values. In general, the mild macrocytic anemia that occurred in male mice was accompanied by a dose-related increase in the incidence of splenic hematopoiesis. The mild macrocytic anemia that occurred with AZT treatment is compatible with the anemia previously reported in mice (Thompson et al., 1991). Macrocytic anemia is a common observation in humans treated with AZT (Snower and Weil, 1993; Richman et al., 1987). The exact mechanism of the erythrocyte macrocytosis is unclear but it likely reflects inhibition of DNA synthesis in erythroid precursors. AZT is directly toxic to erythroid blast forming units (BFU-E) and erythroid colony forming units (CFU-E) in vitro at high concentrations and is antiproliferative in CFU-E at lower concentrations (Gogu et al., 1995). In in vivo studies, AZT has been shown to increase splenic and bone marrow BFU-E in mice and to increase the sensitivity of both splenic and bone marrow BFU-E to erythropoietin (Chow et al., 1991); both effects occur in the absence of an appreciable regenerative response (reticulocytosis), suggesting a maturation block in the erythroid series due to a block in terminal differentiation. AZT has since been shown to down-regulate the erythropoietin receptor in CFU-E and inhibit erythropoietin receptor-mediated signal transduction (Gogu et al., 1995). These mechanisms could inhibit CFU-E proliferation and possibly affect erythropoietin-regulated maturation (Bick, 1993). The absence of reticulocytosis in the presence of a macrocytic anemia subsequent to the administration of AZT in this study is compatible with depression of the erythroid precursors due to impaired DNA synthesis.

Measurable evidence of liver toxicity occurred in mice of both sexes treated with pyrazinamide alone. Male and female-A mice treated with pyrazinamide alone had increased incidences and severity of hepatocullular glycogen depletion accompanied by increased absolute and relative liver weights. Elevated serum enzyme levels did not occur. The hepatocellular glycogen depletion and elevated liver weights that occurred with pyrazinamide treatment are compatible with those previously described (Rao et al., 1998; NIEHS, 2000) in B6C3F1 mice treated with 1,000 or 1,500 mg/kg pyrazinamide. The manifestations of liver toxicity in mice in this study are different from those described in human patients treated with pyrazinamide. Pyrazinamide-induced liver toxicity in human patients (Mandel and Sande, 1990; Durand et al., 1996) is manifested by elevated alanine and aspartate aminotransferase levels and liver necrosis. Liver necrosis and increased liver enzyme levels did not occur in male or female mice in this study.

Administration of AZT and pyrazinamide in combination to male and female mice resulted in exacerbation of the anemia produced by AZT alone. Combination therapy also resulted in thrombocytosis, leukopenia, neutropenia, and lymphopenia. In addition to the splenic hematopoiesis previously described with AZT treatment alone, male mice receiving combination therapy also had a treatment-related depletion of bone marrow. Exacerbation of hematopoietic toxicity subsequent to combination therapy may be the result of pyrazinamide interfering with AZT metabolism. The liver is considered the major site for AZT catabolism and some AZT catabolites are 5- to 7-fold more toxic than AZT (Cretton et al., 1991).

Administration of AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide did not result in significant compound-related alterations in mortality, clinical chemistry parameters, or necropsy findings in mice of either sex. Significant alterations in body weight and body weight gains were not evident in any of the treated male groups. Biologically significant declines in body weight were detected in female mice. Terminal body weights and gravid uterine weights were diminished in female-A mice treated with AZT alone or AZT + pyrazinamide. Corrected body weights for these treatment groups were similar to controls. A slight decline in gestational body weight was evident in the female-B group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide. Significant clinical signs were limited to a few pale animals in the female-A group treated with the highest combination of both test articles. Although occasional statistically significant alterations occurred in epididymal sperm motility, caudal weights, testicular weights, and spermatid heads per gram of testis, none of the sperm function parameters were considered to reflect diminished reproductive capacity.

Measurable evidence of reproductive toxicity was evident in groups treated with AZT alone, pyrazinamide alone, and combinations of AZT and pyrazinamide. Administration of AZT alone resulted in diminished litter size, an increase in the numbers of resorptions, and diminished fetal weights per litter. These alterations have been previously reported in mice treated with AZT alone (NIEHS, 1999). Treatment with pyrazinamide alone resulted in a mild increase in the number of resorptions, diminished fetal weights per litter, and a mild increase in the duration of gestation. In a previous study with lower dosages of pyrazinamide (NIEHS, 1997), significant alterations in reproductive parameters did not occur. Combination therapy resulted in alterations in reproductive parameters of far greater magnitude than detected subsequent to the administration of either test article alone. Combination therapy resulted in a decrease in the number of pregnant females that delivered litters, diminished litter size, an increase in the number of dams with stillborn pups, and a decrease in the number of liveborn pups per litter. During the lactation period, combination therapy resulted in diminished live litter size and an increase in the number of pup deaths. For the mice that were caesarean-sectioned, combination therapy resulted in a diminished number of pregnancies, reduced live litter size, an increase in the number of resorptions, and a decline in fetal weights per litter. Reproductive toxicity with combination therapy may be a reflection of the severity of maternal toxicity, because the reduction in litter size for female-A dams treated for approximately 30 days was far greater than in female-B dams treated for approximately 10 days. Significant numbers of gross external alterations in fetuses did not occur following treatment with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide.

Combinations of AZT at 200 or 400 mg/kg with pyrazinamide at 3,000 mg/kg increased liver weights, increased the hematopoietic toxicity as indicated by anemia, and may have increased the mortality compared to mice treated with the corresponding doses of either drug alone. These effects indicate maternal toxicity at the high dose combinations. Because most reproductive and developmental toxic effects in female mice were observed at the high dose combinations that caused maternal toxicity, increases in reproductive and developmental toxicity at these doses may be secondary to increased maternal toxicity. Pyrazinamide alone up to 10 times the therapeutic dose did not cause biologically significant reproductive, developmental, or general toxicity, which suggests a high safety factor for therapy with pyrazinamide. At 20 times the therapeutic dose, pyrazinamide alone caused a slight increase in liver weights and a significant decrease in mean fetal weight with no significant effects on reproductive parameters.

## Conclusions

Administration of AZT alone (200 or 400 mg/kg per day) to male and female Swiss CD-1® mice caused hematopoietic toxicity manifested primarily by a mild macrocytic anemia. Administration of pyrazinamide alone (300, 1,500, or 3,000 mg/kg per day) resulted in liver toxicity manifested by increased liver weights and hepatocellular glycogen depletion. Pyrazinamide administered in combination with AZT exacerbated the hematopoietic toxicity of AZT.

Regarding reproductive toxicity, administration of AZT alone resulted in an increase in the number of resorptions, diminished litter size, and diminished fetal weights per litter. Pyrazinamide alone resulted in a mild increase in the number of resorptions, diminished fetal body weights per litter, and a mild increase in the duration of gestation. Combination therapy resulted in alterations in the above reproductive parameters of far greater magnitude than those resulting from either compound alone. Other changes evident subsequent to combination therapy consisted of a decrease in the number of pregnant females that delivered litters, diminished litter size, an increase in the number of stillborn pups, and a decrease in the number of liveborn pups per litter. Combination therapy also resulted in diminished live litter size and an increase in the number of pup deaths during the lactation period. Significant numbers of gross external alterations did not occur in fetuses following administration of either compound alone or in combination.

Pyrazinamide alone up to 10 times the therapeutic dose did not cause biologically significant reproductive, developmental, or general toxicity, indicating a high safety factor for therapy with pyrazinamide. Even at 20 times the therapeutic dose, pyrazinamide caused only minimal toxicity. However, results of this study indicate that the toxicological effects of combination therapy could be more severe than the toxicity of individual therapies, even though one of the therapies, such as pyrazinamide, may have minimal toxicity.