# Results

## Survival and Clinical Findings

### Male Mice

Five male mice died during the study (Table 3). Each of the five had been treated with 3,000 mg pyrazinamide/kg body weight alone or in combination with AZT. All were found dead or were sacrificed moribund on day 6, following the initial dose on day 5. Intubation accidents and toxicity due to the highest dose level of pyrazinamide were considered possible causes of mortality; however, neither possibility was confirmed by histopathological findings. The specific cause of death was not determined. The clinical findings (hypoactive, abnormal breathing, cold to the touch, and pallor) in the two male mice sacrificed in a moribund condition were nonspecific and no other significant clinical findings occurred in any of the other male mice during the study.

### Female-A Mice

Four female-A mice died during the study (Table 3), and three of the four had been treated with 200 mg AZT/kg body weight + 3,000 mg pyrazinamide/kg body weight. These three mice were found dead on days 6, 7, and 17, and abnormal clinical findings prior to death did not occur. These deaths were considered possibly related to the 3,000 mg/kg dose of pyrazinamide because five male mice treated with the same dose of pyrazinamide also died. Histopathological lesions confirming pyrazinamide toxicity did not occur, however, and the specific cause of death was not determined.

One female-A mouse treated with 400 mg/kg AZT in combination with 300 mg/kg pyrazinamide was sacrificed moribund on day 18. This mouse was dragging its hindlimbs before death. Histopathological lesions confirming a specific cause of death were not observed.

Four female-A mice treated with 400 mg/kg AZT in combination with 3,000 mg/kg pyrazinamide were pale during the latter stages of the study. None of these mice was pregnant and this clinical finding was believed to reflect anemia. One additional mouse in this group had a red substance in the vagina on days 26 through 29. This mouse had all early resorptions. No other significant clinical signs were observed.

### Female-B Mice

Three female-B mice died prior to the end of the study (Table 3). One female-B mouse treated with 300 mg pyrazinamide/kg body weight had hypoactivity, tremors, labored breathing, and was cold to the touch prior to moribund sacrifice on day 21. One female-B mouse treated with 1,500 mg/kg pyrazinamide and one treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide were found dead on days 19 and 23, respectively. Adverse clinical signs were not observed in these two mice. Histopathology was not performed on these mice, and the specific cause of death was not determined.

One additional female-B mouse treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide had a red substance in the vagina on days 12 through 14 and subsequently had one stillborn pup, two pups of unknown sex and viability, and thirteen implantation sites. No other significant clinical signs were observed in any female-B mice.

TABLE 3 Early Deaths in Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Number of Deaths | Day of Death^b^ | Type of Death | Clinical Findings
Male Mice
0 + 3,000 | 1 | 6 | Found dead | None
200 + 3,000 | 2 | 6 | Found dead | None
| | 6 | Moribund sacrifice | Hypoactive, abnormal breathing, pallor
400 + 3,000 | 2 | 6 | Moribund sacrifice | Hypoactive, cold to touch, abnormal breathing, pallor
| | 6 | Found dead | None
Female-A Mice
200 + 3,000 | 3 | 6 | Found dead | None
| | 17 | Found dead | None
| | 7 | Found dead | None
400 + 300 | 1 | 18 | Moribund sacrifice | Dragging hindlimbs
Female-B Mice
0 + 300 | 1 | 21 | Moribund sacrifice | Hypoactivity, tremors, cold to touch, labored breathing
0 + 1,500 | 1 | 19 | Found dead | None
200 + 3,000 | 1 | 23 | Found dead | None

a AZT + pyrazinamide in mg/kg per day

b Day of death calculated from respective day 0 of study.

## Body Weights and Organ Weights

### Male Mice

#### AZT Alone

Administration of 200 or 400 mg AZT/kg body weight had no biologically or statistically (P≤0.05) significant impact on body weights, body weight gain, epididymal weights, or liver weights (Figures 1 and 2; Tables A1 and A2).

#### Pyrazinamide Alone

Administration of 300, 1,500, or 3,000 mg pyrazinamide/kg body weight generally resulted in treatment-related elevations in mean body weights and mean liver weights (Figures 1 and 2; Tables A1 and A2). Respective final mean body weights for male mice treated with 1,500 or 3,000 mg/kg were approximately 6% (40.33 grams; P≤0.05) and 5% (40.1 grams; P≤0.05) higher than the mean (38.15 grams) in the control group. Mean absolute liver weights for the same treatment groups were approximately 14.2% (2.3780 grams; P≤0.05) and 13.1% (2.3567 grams; P≤0.05) higher than the mean (2.0830 grams) in the control group. Although slightly higher than the control group value, the increases in relative liver weights were not statistically significant (P>0.05). A mild decline (P≤0.05) in the mean relative right epididymal weight occurred in the group treated with 3,000 mg/kg pyrazinamide. The value was approximately 16.7% (1.0 mg/g) lower than the mean (1.2 mg/g) for the controls.

#### AZT and Pyrazinamide Combinations

Administration of combinations of AZT and pyrazinamide resulted in slight elevations in mean body weights (Figure 1; Table A1). For the male group treated with 400 mg/kg AZT weight + 3,000 mg/kg pyrazinamide, the final mean body weight was approximately 8% (41.06 grams; P≤0.05) higher than the mean (38.15 grams) in the control group. The minor elevations in body weight in the other combination treatment groups were not statistically significant (P>0.05).

Considerably more dramatic were treatment-related elevations in absolute and relative liver weights (Figure 2; Table A2). Respective mean absolute liver weights for male mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 3.8% (2.1630 grams), 13.2% (2.3570 grams; P≤0.05), and 21.0% (2.5200 grams; P≤0.05) higher than the mean (2.0830 grams) in the control group. Mean relative liver weight values (Figure 2) for the same treatment groups were approximately 0.4% (54.8 mg/g), 8.8% (59.4 mg/g; P≤0.05), and 16.1% (63.4 mg/g; P≤0.05) higher, respectively, than the mean (54.6 mg/g) for the controls. For the male mice treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean absolute liver weights were approximately 4.6% (2.1780 grams), 11.9% (2.3300 grams; P≤0.05), and 22.4% (2.5500 grams; P≤0.05) higher than the mean (2.0830 grams) in the control group. Respective mean relative liver weights (Figure 2) for the same treatment groups were approximately 2.7% (56.1 mg/g), 9.0% (59.5 mg/g; P≤0.05), and 13.9% (62.2 mg/g; P≤0.05) higher than the mean (54.6 mg/g) for the controls. Significant (P≤0.05) alterations in right epididymal weights did not occur in any of the male groups treated with combinations of AZT and pyrazinamide.

FIGURE 1 Mean Body Weights of Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

(TSAC=Terminal Sacrifice)

FIGURE 2 Mean Relative Liver Weights for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

### Female-A Mice

#### AZT Alone

Female-A mice treated with AZT alone developed dose-related decreases in final mean body weights and gravid uterine weights (Table 4 and Figure 3). Respective mean final body weights in groups treated with 200 or 400 mg AZT/kg body weight were approximately 14% (49.1 grams) and 25% (42.6 grams; P≤0.01) lower than the mean (56.8 grams) in the control group. Gravid uterine weights for the same treatment groups were approximately 35.0% (12.8 grams; P≤0.05) and 66.5% (6.6 grams; P≤0.01) lower than the mean gravid uterine weight (19.7 grams) in the control group. Corrected body weights for female-A mice treated with AZT alone were comparable to those of the control group, indicating that the decreases in final body weights were a reflection of decreased gravid uterine weights subsequent to a reduction in fetal body weights.

Administration of AZT alone to female-A mice resulted in minor dose-related decreases in absolute liver weights (Table A2) and similar dose-related decreases in relative liver weights (Figure 2; Table A2). Respective mean liver weights in female-A groups treated with 200 or 400 mg/kg AZT were approximately 9.9% (2.4387 grams) and 16.6% (2.2581 grams; P≤0.05) lower than the mean (2.7069 grams) in the control group. Respective relative liver weights for the same treatment groups were approximately 7.6% (66.9 mg/g) and 13.9% (62.4 mg/g; P≤0.05) lower than the mean (72.5 mg/g) for the controls.

#### Pyrazinamide Alone

Administration of 300, 1,500, or 3,000 mg pyrazinamide/kg body weight had no biologically significant impact on body weight gains, final mean body weights, or corrected body weights (Table 4 and Figure 3). Treatment-related declines in gravid uterine weights, however, did occur. Respective mean gravid uterine weights for the 300, 1,500, and 3,000 mg/kg treatment groups were approximately 12.2% (17.3 grams), 21.8% (15.4 grams; not significant, P>0.05, due to high variability), and 14.2% (16.9 grams; P≤0.05) lower than the mean (19.7 grams) for the control group. The declines in gravid uterine weights corresponded with diminished fetal body weights.

TABLE 4 Final Body Weights, Gravid Uterine Weights, and Corrected Body Weights of Female-A Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

| | Mean Weights (g) ± Standard Deviation
Dose^a^ | N^b^ | Final Body | Gravid Uterine | Corrected Body^c^
0 + 0 | 13 | 56.8 ± 5.9 | 19.7 ± 4.9^+^ | 37.2 ± 2.7
200 + 0 | 15 | 49.1 ± 8.1 | 12.8 ± 5.9^*^ | 36.3 ± 3.4
400 + 0 | 16 | 42.6 ± 7.6^**^ | 6.6 ± 5.3^**^ | 36.0 ± 3.4
0 + 300 | 15 | 54.6 ± 8.4 | 17.3 ± 7.0 | 37.3 ± 3.4
0 + 1,500 | 12 | 53.4 ± 7.6 | 15.4 ± 6.1 | 38.0 ± 2.2
0 + 3,00 | 13 | 56.2 ± 3.7 | 16.9 ± 1.7^*^ | 39.3 ± 2.8
200 + 300 | 14 | 49.1 ± 8.3 | 12.0 ± 6.0^**^ | 37.0 ± 3.0
200 + 1,500 | 12 | 51.0 ± 8. | 12.9 ± 5.7^*^ | 38.1 ± 2.9
200 + 3,000 | 5 | 37.6 ± 4.0^*^ | 1.8 ± 2.0^*,+^ | 35.8 ± 2.0
400 + 300 | 15 | 44.1 ± 9.1^*^ | 8.2 ± 6.4^**^ | 35.9 ± 3.8
400 + 1,500 | 6 | 44.7 ± 6.5 | 7.9 ± 4.7^*^ | 36.8 ± 2.6
400 + 3,000 | 4 | 39.0 ± 5.9 | 3.0 ± 3.2 | 36.0 ± 3.1

a AZT + pyrazinamide in mg/kg per day

b Number of dams in calculations excludes dams that were not pregnant, that delivered pups prior to scheduled sacrifice, or were sacrificed on an estimated day 14 or day 18 of gestation

c Corrected body weight = final body weight − gravid uterine weight

* P ≤ 0.05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P ≤ 0.01 compared to 0 + 0 (control) group

+ P ≤ 0.05 compared to 200 + 0 group

FIGURE 3 Mean Body Weights of Female-A Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

[TBW=Terminal Body Weight prior to caesarean-section; CBW=Corrected Body Weight; (TBW minus gravid uterine weight); TSAC=Terminal Sacrifice; group mean terminal and corrected body weights include only values for dams that were actually pregnant and that were sacrificed and caesarean-sectioned as scheduled on presumed day 18 of gestation.]

Elevated absolute and relative liver weights also occurred in female-A mice treated with pyrazinamide alone (Figure 2; Table A2). Respective absolute liver weights for the groups treated with 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 2.5% (2.7733 grams), 9.0% (2.9517 grams), and 19.7% (3.2400 grams; P≤0.05) higher than the mean (2.7069 grams) in the control group. Respective mean relative liver weight values were approximately 2.7% (74.5 mg/g), 7.1% (77.6 mg/g), and 13.8% (82.4 mg/g; P<0.05) higher than the mean (72.5 mg/g) for the controls.

#### AZT and Pyrazinamide Combinations

Administration of combinations of AZT and pyrazinamide to female-A mice resulted in decreases in mean final body weights. Respective mean final body weights (Table 4 and Figure 3) for female-A mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 14% (49.07 grams), 10% (51.00 grams), and 34% (37.60 grams; P≤0.05) lower than the mean (56.85 grams) in the control group. For the female-A mice treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean final body weights were approximately 22% (44.07 grams; P≤0.05), 21% (44.67 grams), and 31% (39.00 grams) lower than the mean (56.85 grams) for the controls. Lower gravid uterine weights (Table 4) accompanied the declines in final mean body weights. Respective mean gravid uterine weights for female-A mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 39.1% (12.0 grams; P≤0.01), 34.5% (12.9 grams; P≤0.05), and 90.9% (1.8 grams; P≤0.05) lower than the mean (19.7 grams) for the controls. For the female-A groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean gravid uterine weights were approximately 58.4% (8.2 grams; P<0.01), 59.9% (7.9 grams; P<0.05), and 84.8% (3.0 grams; not significant, P>0.05, due to few pregnant mice) lower than the mean (19.7 grams) in the control group. Combination therapy had no impact on corrected final body weights (Table 4) as they were comparable for all treatment groups.

Combination therapy did not result in significant alterations in absolute liver weights (Table A2). For the female-A groups treated with 200 mg/kg AZT + 1,500 mg/kg pyrazinamide and 400 mg/kg AZT + 3,000 mg/kg pyrazinamide, respective mean relative liver weights were 7.7% (78.1 mg/g; P≤0.05) and 9.1% (79.1 mg/g) higher than the mean (72.5 mg/g) for the controls (Figure 2). Slight declines in mean relative liver weights occurred in all other groups of female-A mice receiving combination therapy.

### Female-B Mice

#### AZT Alone

Significant (P≤0.05) alterations in gestational body weights did not occur in female-B mice treated with 200 or 400 mg/kg AZT alone (Figure 4; Table A1). Average body weights and body weight gains during the lactation period did not differ statistically (P>0.05) from those of the control group.

#### Pyrazinamide Alone

Administration of 300, 1,500, or 3,000 mg/kg pyrazinamide alone to female-B mice did not result in significant alterations (P>0.05) in mean body weights during the gestation or lactation period (Figure 4; Table A1).

#### AZT and Pyrazinamide Combinations

With the exception of the high-dose combination group, biologically significant alterations in body weights of female-B mice treated with AZT and pyrazinamide did not occur during the gestation or lactation period (Figure 4; Table A1). On day 15 of gestation, the mean body weight for the female-B group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide was approximately 12% (43.7 grams; P≤0.05) lower than the mean (49.8 grams) in the control group. During the lactation period, mean body weights were slightly reduced in female-B mice treated with the higher combinations of AZT and pyrazinamide, but these values were not statistically different (P>0.05) from the control group.

FIGURE 4 Mean Body Weights of Female-B Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

(GD=Gestation Day; LD=Lactation Day; group mean weights include only values for those dams that were actually pregnant, that survived to lactation day 4, and that delivered pups that survived to lactation day 4.)

## Clinical Pathology

### Hematology

Although it is difficult to compare results between males and females or between groups dosed differently, it appears that the duration of treatment had a major impact on the severity of the hematology results. Severity was greatest in female-A mice dosed for approximately 30 days. Alterations were not as prominent in the males dosed for approximately 20 days, and the female-B groups dosed for approximately 10 days had rather mild alterations. Specific details for male, female-A, and female-B mice are discussed in the following sections.

#### Male Mice

In general, male mice treated with AZT alone developed a slight macrocytic anemia and thrombocytosis. Administration of pyrazinamide alone had no impact on erythrocyte (RBC) parameters. Combination therapy with AZT and pyrazinamide resulted in a mild to moderate anemia and thrombocytosis, and the severity of the anemia and thrombocytosis was greater than that observed subsequent to treatment with AZT alone.

#### AZT Alone

Administration of AZT alone to male mice resulted in a slight decline in mean RBC counts (Figure 5; Table B1). Although not statistically significant (P>0.05), respective mean RBC counts in male mice treated with 200 or 400 mg AZT/kg body weight were approximately 12% (8.22 × 10^6^/μL) and 13% (8.18 × 10^6^/μL) lower than the mean RBC count (9.37 × 10^6^/μL) in the control group. Reduced hemoglobin (HGB) and hematocrit (HCT) values paralleled the dose-related declines in RBC counts (Table B1). Slight elevations in mean cell volume (MCV) and mean cell hemoglobin (MCH) also accompanied the slight anemia. Respective MCV values for male mice treated with 200 or 400 mg/kg of AZT (Figure 6; Table B1) were approximately 10% (53.2 fL; P≤0.01) and 11% (53.6 fL; P≤0.01) higher than the mean (48.2 fL) in the control group. The MCH values (Table B1) in both treatment groups were approximately 7% (17.5 pg) higher than the mean (16.4 pg) in the control group. Reticulocyte counts were only slightly elevated.

Although not statistically significant (P>0.05), platelet counts in both male groups treated with AZT alone were slightly higher than the control group value (Table B1). Respective mean platelet counts in male mice treated with 200 or 400 mg/kg AZT were approximately 1.2 times (1,147 × 10^3^/μL) and 1.2 times (1,129 × 10^3^/μL) the mean (932 × 10^3^/μL) in the control group (Figure 7).

Figure 5 Mean Red Blood Cell (Erythrocyte) Counts for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

FIGURE 6 Mean Corpuscular Volumes for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

FIGURE 7 Mean Platelet Counts for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

#### Pyrazinamide Alone

Administration of 300, 1,500, or 3,000 mg/kg pyrazinamide alone to male mice did not result in statistically significant alterations (P>0.05) in any of the hematology parameters (Table B1). Although not statistically significant (P>0.05), mean platelet counts in the two highest dose groups were slightly higher than the platelet count in the controls. Respective mean platelet counts (Figure 7; Table B1) in male mice treated with 1,500 or 3,000 mg/kg pyrazinamide were approximately 1.1 times (1,059 × 10^3^/μL) and 1.2 times (1,163 × 10^3^/μL) the mean platelet count (932 × 10^3^/μL) in the control group.

#### AZT and Pyrazinamide Combinations

The most significant hematology alterations in male mice treated with combinations of AZT and pyrazinamide consisted of mild to moderate treatment-related anemia and thrombocytosis (Table B1). The severity of the anemia and thrombocytosis was greater than that detected subsequent to treatment with AZT alone. Respective mean RBC counts in male mice (Figure 5) treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 10% (8.47 × 10^6^/μL), 13% (8.14 × 10^6^/μL), and 38% (5.78 × 10^6^/μL; P≤0.01) lower than the RBC count (9.37 × 10^6^/μL) in the control group. Respective mean RBC counts detected in male mice treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide (Figure 5) were approximately 12% (8.27 × 10^6^/μL), 15% (7.94 × 10^6^/μL; P≤0.05), and 39% (5.71 × 10^6^/μL; P≤0.01) lower than the mean (9.37 × 10^6^/μL) in the controls. Diminished HGB and HCT values paralleled the declines in RBC counts (Table B1). Treatment-related elevations in MCV and MCH values occurred only in male groups treated with AZT + 300 or 1,500 mg/kg pyrazinamide (Table B1). Respective MCV values in male mice (Figure 6) treated with 200 mg/kg AZT + 300 or 1,500 mg/kg of pyrazinamide were approximately 7% (51.5 fL) and 10% (53.2 fL; P≤0.01) higher than the MCV value (48.2 fL) in the control group. Respective MCV values in male mice (Figure 6) treated with 400 mg/kg AZT + 300 or 1,500 mg/kg pyrazinamide were approximately 9% (52.6 fL; P≤0.05) and 10% (52.9 fL; P≤0.01) higher than the mean (48.2 fL) in the controls. Although not statistically significant (P>0.05), respective MCH values (Table B1) in male mice treated with 200 mg/kg AZT + 300 or 1,500 mg/kg pyrazinamide were approximately 5% (17.3 pg) and 7% (17.6 pg) higher than the mean (16.4 pg) in the controls. MCH values for both groups treated with 400 mg/kg AZT + 300 or 1,500 mg/kg pyrazinamide were approximately 7% (17.5 pg) higher than the mean (16.4 pg) in the controls. Significant (P≤0.05) elevations in MCV and MCH values did not occur in male mice treated with 200 or 400 mg/kg AZT + 3,000 mg/kg pyrazinamide.

Mild declines in reticulocyte counts accompanied the anemia in the male groups treated with AZT in combination with the highest dose of pyrazinamide (Table B1). Although not statistically significant (P>0.05), respective reticulocyte counts (Figure 8) in male mice treated with 200 or 400 mg/kg AZT + 3,000 mg/kg pyrazinamide were approximately 34% (3.3 × 10^5^/μL) and 40% (3.0 × 10^5^/μL) lower than the mean (5.0 × 10^5^/μL) in the controls. Biologically significant alterations in reticulocyte counts did not occur in the male groups treated with AZT in combination with 300 or 1,500 mg/kg pyrazinamide (Table B1).

FIGURE 8 Mean Reticulocyte Counts for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

A distinct dose-related elevation in platelet counts (Table B1) occurred in male mice treated with combinations of AZT and pyrazinamide, and the severity of the thrombocytosis was considerably greater than that in male mice treated with either compound alone. Respective mean platelet counts in male groups (Figure 7) treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 1.3 times (1,247 × 10^3^/μL), 1.7 times (1,553 × 10^3^/μL; P≤0.01), and 2.1 times (1,978 × 10^3^/μL; P≤0.01) the mean (932 × 10^3^/μL) in the control group. Respective mean platelet counts in male mice (Figure 7) treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 1.2 times (1,172 × 10^3^/μL), 1.5 times (1,420 × 10^3^/μL; P≤0.01), and 2 times (1,824 × 10^3^/μL; P≤0.01) the mean platelet count (932 × 10^3^/μL) for the controls.

Although not statistically significant (P>0.05), biologically significant declines in total leukocyte (WBC) counts (Table B1) occurred in male mice treated with 200 or 400 mg/kg AZT + 3,000 mg/kg pyrazinamide. Respective mean WBC counts for these treatment groups (Figure 9) were approximately 20% (4.93 × 10^3^/μL) and 42% (3.58 × 10^3^/μL) lower than the mean WBC count (6.19 × 10^3^/μL) in the male control group. Evaluation of the differential data revealed declines in neutrophil and lymphocyte counts (Table B1). Respective mean neutrophil counts in male mice (Figure 10) treated with 200 or 400 mg/kg AZT + 3,000 mg/kg of pyrazinamide were approximately 19% (0.81 × 10^3^/μL) and 23% (0.77 × 10^3^/μL) lower than the mean neutrophil count (1.00 × 10^3^/μL) in the controls. Respective mean lymphocyte counts for the same treatment groups were approximately 22% (3.72 × 10^3^/μL) and 49% (2.44 × 10^3^/μL) lower than the mean (4.77 × 10^3^/μL) in the controls.

#### Female-A Mice

In general, the hematological alterations induced by AZT alone were slightly more severe in female-A mice than in males. Administration of pyrazinamide alone to female-A mice did not result in biologically significant hematological changes. Combination therapy with AZT and pyrazinamide resulted in a prominent anemia, leukopenia, and thrombocytosis. As with the males, the severity of these hematological alterations was greater than that induced by AZT alone.

#### AZT Alone

Administration of AZT alone to female-A mice resulted in a mild anemia (Table B1). Respective mean RBC counts detected in female-A mice (Figure 5) treated with 200 or 400 mg AZT/kg body weight were approximately 14% (7.88 × 10^6^/μL; P≤0.01) and 17% (7.62 × 10^6^/μL; P≤0.01) lower than the mean RBC count (9.14 × 10^6^/μL) in the controls. Mild declines in HGB and HCT values (Table B1) paralleled the dose-related decline in RBC counts. The anemia was accompanied by dose-related elevations in MCV and MCH values (Table B1). Respective MCV values (Figure 6) in female-A mice treated with 200 or 400 mg AZT/kg body weight were approximately 14% (56.4 fL; P≤0.01) and 18% (58.3 fL; P≤0.01) higher than the MCV value (49.3 fL) in the controls. Respective MCH values (Table B1) for the same treatment groups were approximately 12% (18.4 pg; P≤0.01) and 14% (18.8 pg; P≤0.01) higher than the mean (16.5 pg) in the controls. Reticulocyte counts (Figure 8; Table B1) were within a normal range.

FIGURE 9 Mean White Blood Cell (Leukocyte) Counts for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

FIGURE 10 Mean Neutrophil Counts for Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Although not statistically significant (P>0.05), platelet counts were slightly elevated in female-A mice treated with AZT alone (Figure 7; Table B1). Respective mean platelet counts in groups treated with 200 or 400 mg/kg AZT were approximately 1.1 times (1,319 × 10^3^/μL) and 1.2 times (1,378 × 10^3^/μL) the mean (1,190 × 10^3^/μL) in the controls.

Although not statistically significant (P>0.05), a slight leukopenia also occurred in female-A mice treated with AZT alone (Table B1). Respective mean WBC counts (Figure 9) in groups treated with 200 or 400 mg/kg AZT were approximately 13% (5.95 × 10^3^/μL) and 14% (5.86 × 10^3^/μL) lower than the mean (6.85 × 10^3^/μL) in the control group. Evaluation of the differential data revealed a slight neutropenia (Table B1). Respective mean neutrophil counts (Figure 10) in female-A mice treated with 200 or 400 mg/kg AZT were approximately 22% (1.43 × 10^3^/μL) and 30% (1.29 × 10^3^/μL) lower than the mean neutrophil count (1.83 × 10^3^/μL) in the control group.

#### Pyrazinamide Alone

Biologically significant alterations did not occur in any of the hematology parameters in female-A mice treated with pyrazinamide alone.

#### AZT and Pyrazinamide Combinations

Combination therapy with AZT and pyrazinamide in female-A mice resulted in treatment-related anemia, thrombocytosis, and leukopenia (Table B1).

The anemia induced by combination therapy in female-A mice was similar in severity to the anemia caused by AZT alone except for the group treated with the highest combination. Respective mean RBC counts in female-A mice (Figure 5; Table B1) treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 13% (7.94 × 10^6^/μL; P≤0.01), 13% (7.91 × 10^6^/μL; P≤0.01), and 14% (7.88 × 10^6^/μL; P≤0.01) lower than the mean (9.14 × 10^6^/μL) in the control group. Respective mean RBC counts in female-A mice (Figure 5) treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg of pyrazinamide were approximately 13% (7.98 × 10^6^/μL; P≤0.01), 14% (7.82 × 10^6^/μL; P≤0.01), and 38% (5.69 × 10^6^/μL; P≤0.01) lower than the mean (9.14 × 10^6^/μL) in the controls. Diminished HGB and HCT values (Table B1) accompanied the declines in RBC counts. With the exception of the group receiving the highest combination dose, marked elevations in MCV and MCH values (Table B1) accompanied the anemia. The elevated MCV values occurred in the absence of concurrent elevations in reticulocyte counts (Table B1). Respective MCV values (Figure 6) for female-A mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 14% (56.1 fL; P≤0.01), 19% (58.5 fL; P≤0.01), and 18% (58.2 fL; P≤0.01) higher than the mean (49.3 fL) in the controls. For the groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective MCV values (Figure 6) were approximately 16% (57.0 fL; P≤0.01), 18% (58.2 fL; P≤0.01), and 9% (53.6 fL; P≤0.01) higher than the mean (49.3 fL) in the controls. Respective MCH values (Table B1) in female-A mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg of pyrazinamide were approximately 14% (18.8 pg; P≤0.01), 15% (19.0 pg; P≤0.01), and 16% (19.2 pg; P≤0.01) higher than the mean (16.5 pg) in the control group. For the groups treated with 400 mg/kg of AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective MCH values were approximately 14% (18.8 pg; P≤0.01), 16% (19.1 pg; P≤0.01), and 8% (17.8 pg; P≤0.01) higher than the mean (16.5 pg) for the controls. The reason for the lower MCV and MCH values in the highest dose combination group was not evident. Reticulocyte counts were within a normal range.

A prominent thrombocytosis occurred in the highest dose combination group (Table B1). For the female-A group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide, the mean platelet count (Figure 7) was approximately 1.8 times (2,166 × 10^3^/μL; P≤0.01) the mean (1,190 × 10^3^/μL) in the control group. Mean platelet counts in all other female-A combination groups were within 10% of the mean in the controls.

A treatment-related leukopenia occurred in female-A mice receiving combination therapy, and the severity of this leukopenia was greater than that in groups treated with AZT alone (Table B1). Respective mean WBC counts in female-A mice (Figure 9) treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 20% (5.49 × 10^3^/μL), 23% (5.25 × 10^3^/μL; P≤0.05), and 38% (4.28 × 10^3^/μL; P≤0.01) lower than the mean (6.85 × 10^3^/μL) in the control group. For the female-A groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean WBC counts (Figure 9) were approximately 18% (5.61 × 10^3^/μL), 27% (4.97 × 10^3^/μL; P≤0.01), and 39% (4.21 × 10^3^/μL; P≤0.01) lower than the mean (6.85 × 10^3^/μL) for the controls. Evaluation of the differential data revealed treatment-related declines in neutrophils and lymphocytes (Table B1). Respective mean neutrophil counts (Figure 10) for female-A mice treated with 200 mg/kg of AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 30% (1.28 × 10^3^/μL), 37% (1.16 × 10^3^/μL), and 46% (0.98 × 10^3^/μL; P≤0.05) lower than the mean neutrophil count (1.83 × 10^3^/μL) in the control group. For the female-A groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean neutrophil counts were approximately 46% (0.99 × 10^3^/μL; P≤0.05), 52% (0.88 × 10^3^/μL; P≤0.01), and 61% (0.71 × 10^3^/μL; P≤0.01) lower than the mean (1.83 × 10^3^/μL) in the controls. Respective mean lymphocyte counts (Table B1) for female-A mice treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide were approximately 15% (3.93 × 10^3^/μL), 19% (3.74 × 10^3^/μL), and 34% (3.02 × 10^3^/μL) lower than the mean (4.61 × 10^3^/μL) in the control group. For the groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean lymphocyte counts were approximately 6% (4.32 × 10^3^/μL), 19% (3.74 × 10^3^/μL), and 30% (3.23 × 10^3^/μL) lower than the mean (4.61 × 10^3^/μL) in the controls. Although only a small part of the differential count, monocytes were lower in all female-A groups treated with combination therapy (Table B1). Monocyte counts ranged from 19% (0.17 × 10^3^/μL) to 38% (0.13 × 10^3^/μL; P≤0.05) lower than the mean (0.21 × 10^3^/μL) in the control group. Biologically significant alterations did not occur in any of the other differential leukocyte parameters.

#### Female-B Mice

In general, hematological alterations in female-B mice treated for a shorter duration (approximately 10 days) were considerably less than those described for female-A mice. Anemia did not occur in female-B mice treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide.

#### AZT Alone

Biologically and statistically (P≤0.05) significant alterations in female-B mice treated with 200 or 400 mg AZT/kg body weight were limited to a mild elevation in the MCV value in the high dose group (Table B1). The mean MCV value in the female-B group treated with 400 mg/kg AZT was approximately 5% (53.6 fL; P≤0.05) higher than the mean (51.1 fL) in the control group. No other hematological alterations occurred.

#### Pyrazinamide Alone

Administration of 300, 1,500, or 3,000 mg pyrazinamide/kg body weight to female-B mice did not result in any biologically or statistically (P≤0.05) significant alterations in any of the hematology parameters.

#### AZT and Pyrazinamide Combinations

Hematological alterations in female-B mice treated with combination therapy were limited to minor elevations in MCV and MCH values. Anemia did not occur. For the female-B mice treated with 200 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide, respective MCV values (Table B1) were approximately 9% (55.5 fL; P≤0.01) and 7% (54.6 fL; P≤0.01) higher than the mean (51.1 fL) in the control group. Administration of 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide resulted in respective MCV values approximately 6% (54.3 fL; P≤0.01), 5% (53.8 fL; P≤0.01), and 4% (53.2 fL) higher than the mean (51.1 fL) in the controls. The reason for the lower value in the highest-dose combination group was not apparent. Elevations in MCH values (Table B1) were less dramatic, with increases in only three groups. Respective MCH values in female-B mice treated with 200 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide were approximately 8% (18.3 pg; P≤0.01) and 6% (18.1 pg; P≤0.01) higher than the mean (17.0 pg) in the controls. The MCH value in the group treated with 400 mg/kg AZT + 1,500 mg/kg pyrazinamide was approximately 5% (17.9 pg; P≤0.01) higher than the mean (17.0 pg) in the control group. Biologically significant alterations did not occur in RBC, WBC, reticulocyte, or platelet values of any of the female-B groups receiving combination therapy.

#### Clinical Chemistry

Administration of 200 or 400 mg AZT/kg body weight, 300, 1,500, or 3,000 mg pyrazinamide/kg body weight, or combinations of AZT and pyrazinamide to male and female-A mice did not result in biologically or statistically (P≤0.05) significant alterations in clinical chemistry parameters (Table B2).

## Necropsy Observations

The only lesion found at necropsy believed possibly related to treatment was an enlarged spleen observed in a single male mouse treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide. Bone deformity (thoracic vertebrae or ribs) occurred randomly in male and female mice from a variety of treatment groups and may have been secondary to the physical effect of twice daily gavage dosing. Other lesions such as small thymus, small testis, focus on the testis, focus on the liver, small epididymis, and hemorrhage in subcutaneous tissue occurred sporadically with a low incidence and were considered to be spontaneous and unrelated to treatment.

## Histopathologic Observations

Representative microscopic lesions resulting from administration of AZT and pyrazinamide are listed in Table 5 and illustrated in Plates 1 to 6. Target tissues included the bone marrow, liver, and spleen of male mice and the liver of female-A mice. Statistical results include dose-response effects of AZT and pyrazinamide compared to the vehicle control group as well as significant dose-response effects in the presence of fixed levels of AZT and pyrazinamide.

TABLE 5 Representative Microscopic Lesions (Photomicrographs) Related to Treatment in Adult Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Tissue | Magnification | Plate Number | Lesion
0 + 0 | Liver | H160 | 1 | None (control)
400 + 3,000 | Liver | H160 | 2 | Glycogen depletion, moderate
0 + 0 | Spleen | H160 | 3 | None (control)
400 + 3,000 | Spleen | H160 | 4 | Hematopoietic cell proliferation, moderate
0 + 0 | Bone Marrow | H160 | 5 | None (control)
400 + 3,000 | Bone Marrow | H160 | 6 | Cellular depletion, mild

a AZT + pyrazinamide in mg/kg per day

PLATE 1 Liver from a control male mouse showing normally glycogenated hepatocytes. (x160)

PLATE 2 Liver from a male mouse treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide showing moderate glycogen depletion. (x160)

PLATE 3 Spleen from a control male mouse showing essentially normal hematopoietic cells. (x160)

PLATE 4 Spleen from a male mouse treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide showing moderate hematopoietic cell proliferation. (x160)

PLATE 5 Bone marrow from a control male mouse showing essentially normal hematopoietic elements. (x160)

PLATE 6 Bone marrow from a male mouse treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide showing mild cellular depletion. (x160)

### Liver Lesions

Administration of AZT and pyrazinamide resulted in an increased incidence of a cytoplasmic alteration in hepatocytes diagnosed as glycogen depletion (Table 6). As glycogen does not stain with routine hematoxylin and eosin stains, this diagnosis represents a cytoplasmic alteration in hepatocytes manifested by diminished vacuolization. Criteria for severity grades of glycogen depletion of hepatocytes were:

- Minimal severity - a slight reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending not more than 1/3 to 1/2 the distance through the liver lobule from the central to portal veins
- Mild severity - an almost complete reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending not more than 1/3 to 1/2 the distance through the liver lobule from the central to portal veins
- Moderate severity - an almost complete reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending 1/2 the distance or more through the liver lobule from the central to portal veins
- Marked severity - an absence of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes.

Administration of AZT alone to male and female-A mice did not result in statistically significant increases (P>0.05) in the severity of glycogen depletion (Table 7). Compared to the vehicle control group, male and female-A mice treated with 1,500 or 3,000 mg/kg pyrazinamide alone had increased scores (P≤0.01) for glycogen depletion. Compared to the male groups treated with 200 or 400 mg/kg AZT alone, the male mice that received 200 or 400 mg/kg AZT + 300 mg/kg pyrazinamide had significant (P≤0.05) increases in the severity of glycogen depletion. A similar significant (P≤0.05) increase in severity occurred in the female-A group treated with 400 mg/kg AZT + 300 mg/kg pyrazinamide, when compared to the female group treated with 400 mg/kg AZT alone. Compared to male and female-A groups treated with 200 or 400 mg/kg AZT alone, groups treated with AZT + 1,500 or 3,000 mg/kg pyrazinamide had even more significant (P≤0.01) increases in severity of glycogen depletion. The group with the highest incidence and greatest severity grade was the female-A group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide. The severity score for this group was significant (P≤0.01) when compared to the female-A group treated with 3,000 mg/kg pyrazinamide alone, indicating that the addition of 400 mg/kg AZT enhanced the severity of glycogen depletion. In general, the degree of severity of glycogen depletion correlated with increased relative liver weights. Necrosis of hepatocytes did not occur and a discernable increase in the size of the cells was not evident.

TABLE 6 Incidence and Severity of Hepatocellular Glycogen Depletion in Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Males | | Females-A
Dose^a^ | Group Incidence^b^ | Mean Severity^c^ | Group Incidence^b^ | Mean Severity^c^
0 + 0 | 2/10 | 3.0 | 6/20 | 2.5
200 + 0 | 2/10 | 2.5 | 11/20 | 2.8
400 + 0 | 6/10 | 2.2 | 8/20 | 2.6
0 + 300 | 6/10 | 2.5 | 11/20 | 2.2
0 + 1,500 | 10/10 | 2.9 | 20/20 | 3.1
0 + 3,000 | 9/10 | 3.2 | 20/20 | 3.1
200 + 300 | 8/10 | 2.5 | 16/20 | 2.4
200 + 1,500 | 10/10 | 3.3 | 20/20 | 3.0
200 + 3,000 | 9/10 | 3.3 | 17/20 | 3.2
400 + 300 | 8/10 | 3.0 | 17/20 | 2.9
400 + 1,500 | 10/10 | 3.2 | 20/20 | 3.0
400 + 3,000 | 9/10 | 3.6 | 20/20 | 3.8

a AZT + pyrazinamide in mg/kg per day

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity for mice with the lesion (grade: 1=minimal, 2=mild, 3=moderate, and 4=marked)

TABLE 7 Statistical Analysis of Severity of Hepatocellular Glycogen Depletion in Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | [underlined: Severity^b^ in Male Mice]- | | | [underlined: Severity^b^ in Female-A Mice]
Dose^a^ | Mean^c^ | S.E. | Ratio^d^ | Mean^c^ | S.E. | Ratio
0+0 | 0.600 | 0.427 | - | 0.750 | 0.280 | -
200+0 | 0.500 | 0.342 | 83 | 1.550 | 0.336 | 207
400+0 | 1.300 | 0.367 | 217 | 1.050 | 0–312 | 140
| Trend^e^ | +(P=0 109) | | Trend^e^ | +(P=0.492)
| Test Used^f^ | Dunn | | Test Used^f^ | Dunn
0+0 | 0.600 | 0.427 | - | 0.750 | 0.280 | -
0+300 | 1.500 | 0.428 | 250 | 1.200 | 0.258 | 160
0+1,500 | **2.900 | 0.100 | 483 | **3.050 | 0.088 | 407
0+3,000 | **2–900 | 0–379 | 483 | **3.050 | 0.153 | 407
| Trend^e^ | +(P≤0.001) | | Trend^e^ | +(P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
200+0 | 0.500 | 0.342 | - | 1.550 | 0.336 | -
200+300 | *2.000 | 0.365 | 400 | 1.950 | 0256 | 126
200+1,500 | **3.300 | 0.153 | 660 | **3.000 | 0.126 | 194
200+3,000 | **3.000 | 0.365 | 600 | **2.700 | 0.300 | 174
| Trend^e^ | +(P≤0.001) | | Trend^e^ | +(P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
400+0 | 1.300 | 0.367 | - | 1.050 | 0.312
400+300 | *2.400 | 0.427 | 185 | **2.500 | 0.286 | 238
400+1,500 | **3.200 | 0.200 | 246 | **3.000 | 0.126 | 286
400+3,000 | **3.200 | 0–389 | 246 | **3.750 | 0.099 | 357
| Trend^e^ | +(P≤0.001) | | Trend^e^ | +(P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley
0+3,000 | 2.900 | 0.379 | - | 3.050 | 0.153
200+3,000 | 3.000 | 0.365 | 103 | 2.700 | 0.300 | 89
400+3,000 | 3.200 | 0.389 | 110 | **3.750 | 0.099 | 123
| Trend^e^ | −(P≤0.001) | | Trend^e^ | −(P≤0.001)
| Test Used^f^ | Shirley | | Test Used^f^ | Shirley

a AZT + pyrazinamide in mg/kg per day

b Severity grade is presented as mean severity for all mice in group, including those with no lesion (0=normal, 1=minimal, 2=mild, 3=moderate, and 4=marked), and standard error (S.E.)

c n=1 0 for male groups and 20 for female-A groups

d Dosed group mean/control group mean) x 100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Bone Marrow Lesions

Cellular depletion (depletion of hematopoietic cells) of bone marrow occurred only in male groups treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide and 400 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide (Table 8). Criteria for severity of bone marrow lesions were as follows:

- Minimal severity - Depletion of approximately 5% or less of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region
- Mild severity - Depletion of approximately 6% to 20% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region
- Moderate severity - Depletion of approximately 21% to 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region
- Marked severity - Depletion of more than 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region.

Compared to the male group treated with AZT alone, the severity was statistically significant (P≤0.05 to P≤0.01) in all three treatment groups (Table 9) and peaked in the group treated with the highest dose combination of AZT and pyrazinamide. In general, the degree of severity of bone marrow depletion corresponded with lower erythrocyte counts in the peripheral circulation.

TABLE 8 Incidence and Severity of Cellular Depletion of Bone Marrow in Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Group Incidence^b^ | Mean Severity^c^
0 + 0 | 0/10 | −
200 + 3,000 | 4/10 | 1.8
400 + 1,500 | 3/10 | 1.3
400 + 3,000 | 5/10 | 2.0

Note: The lesion did not occur in dose groups not listed.

a AZT + pyrazinamide in mg/kg per day

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity for mice with the lesion (grade: 1=minimal, 2=mild, 3=moderate, and 4=marked)

TABLE 9 Statistical Analysis of Mean Severity of Cellular Depletion of Bone Marrow in Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ (Combination Groups Only) | Severity^b^
Dose^a^ (Combination Groups Only) | Mean^c^ | S.E.
200 + 0 | 0.000 | 0.000
200 + 300 | 0.000 | 0.000
200 + 1,500 | 0.000 | 0.000
200 + 3,000 | **0.700 | 0.300
| Trend^d^ + (P=0.005)
| Test Used^e^ Shirley
400 + 0 | 0.000 | 0.000
400 + 300 | 0.000 | 0.000
400 + 1,500 | *0.400 | 0.221
400 + 3,000 | **1.000 | 0.365
| Trend^d^ + (P=0.001)
| Test Used^e^ Shirley

a AZT + pyrazinamide in mg/kg per day

b Severity grade is presented as mean severity for all mice in group, including those with no lesion (0=normal, 1=minimal, 2=mild, 3=moderate, and 4=marked), and standard error (S.E.)

c n=10

d Direction and significance of trend (Jonckheere’s test)

e Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Spleen Lesions

Hematopoietic cell proliferation of the spleen occurred in all male groups treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide (Table 10). Criteria for severity grades for hematopoietic cell proliferation were as follows:

- Minimal severity - Approximately 15% or less of the red pulp is occupied by hematopoietic cells
- Mild severity - Approximately 16% to 50% of the red pulp is occupied by hematopoietic cells
- Moderate severity - Approximately 51% to 90% of the red pulp is occupied by hematopoietic cells
- Marked severity - Approximately 91% to 100% of the red pulp is occupied by hematopoietic cells

Compared to the vehicle control group, the degree of severity was significant (P≤0.01) in the group treated with 400 mg AZT alone (Table 11). The degree of severity was not statistically significant (P>0.05) in the male groups treated with pyrazinamide alone (compared to the vehicle controls) or combinations of AZT and pyrazinamide (compared to the group treated with AZT alone), indicating that this cellular response was primarily induced by AZT. Splenic hematopoiesis corresponded, in general, with declines in peripheral erythrocyte counts.

TABLE 10 Incidence and Severity of Spleen Hematopoiesis in Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Group Incidence^b^ | Mean Severity^c^
0 + 0 | 1/10 | 2.0
200 + 0 | 4/10 | 2.5
400 + 0 | 7/10 | 2.4
0 + 300 | 1/10 | 2.0
0 + 1,500 | 4/10 | 2.0
0 + 3,000 | 3/10 | 2.3
200 + 300 | 5/10 | 2.2
200 + 1,500 | 6/10 | 2.3
200 + 3,000 | 2/10 | 3.0
400 + 300 | 7/10 | 2.0
400 + 1,500 | 8/10 | 2.1
400 + 3,000 | 5/10 | 2.4

a AZT + pyrazinamide in mg/kg per day

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity for mice with the lesion (grade: 1=minimal, 2=mild, 3=moderate, and 4=marked).

TABLE 11 Statistical Analysis of Severity of Splenic Hematopoiesis in Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Severity^b^
Dose^a^ | Mean^c^ | S.E. | Ratio^d^
0 + 0 | 0.200 | 0.200 | −
200 + 0 | 1.000 | 0.447 | 500
400 + 0 | **1.700 | 0.396 | 850
Trend^e^ + (P=0.006)
Test Used^f^ Shirley
0 + 0 | 0.200 | 0.200 | −
0 + 300 | 0.200 | 0.200 | 100
0 + 1,500 | 0.800 | 0.327 | 400
0 + 3,000 | 0.700 | 0.367 | 350
Trend^e^ + (P=0.110)
Test Used^f^ Shirley
200 + 0 | 1.000 | 0.447 | −
200 + 300 | 1.100 | 0.379 | 110
200 + 1,500 | 1.400 | 0.400 | 140
200 + 3,000 | 0.600 | 0.427 | 60
Trend^e^ − (P=0.604)
Test Used^f^ Shirley
400 + 0 | 1.700 | 0.396 | −
400 + 300 | 1.400 | 0.306 | 82
400 + 1,500 | 1.700 | 0.300 | 100
400 + 3,000 | 1.200 | 0.442 | 71
Trend^e^ −(P=0.488)
Test Used^f^ Shirley

a AZT + pyrazinamide in mg/kg per day

b Severity grade is presented as mean severity for all mice in group, including those with no lesion (0=normal, 1=minimal, 2=mild, 3=moderate, and 4=marked), and standard error (S.E.)

c n=10

d (Dosed group mean/control group mean) × 100

e Direction and significance of trend (Jonckheere’s test)

f Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

Atrophy of the splenic red pulp occurred in three male mice each in the groups treated with 200 or 400 mg AZT + 3,000 mg pyrazinamide (Table 12). Splenic red pulp atrophy was graded for severity based on the following criteria:

- Minimal severity – depletion of approximately 5% or less of normal red pulp cell population (erythroid cells, myeloid cells, megakaryocytes)
- Mild severity - depletion of approximately 6 to 20% of normal red pulp cell population
- Moderate severity - depletion of approximately 21 to 50% of normal red pulp cell population
- Marked severity – depletion of 51% or greater of normal red pulp cell population.

The splenic atrophy that occurred in these mice likely contributed to a lowered incidence of splenic hematopoiesis in these two treatment groups. Compared to the group treated with AZT alone, the severity was significant (P≤0.05) in both treatment groups (Table 13) and corresponded with the hematological finding of anemia.

TABLE 12 Incidence and Severity of Red Pulp Atrophy of the Spleen in Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Group Incidence^b^ | Mean Severity^c^
0 + 0 | 0/10 | B
200 + 3,000 | 3/10 | 2.0
400 + 3,000 | 3/10 | 2.3

Note: The lesion did not occur in dose groups not listed.

a AZT + pyrazinamide in mg/kg per day

b Number of animals in group with lesion/number of animals with tissue examined microscopically.

c Mean severity for mice with the lesion (grade: 1=minimal, 2=mild, 3=moderate, and 4=marked)

TABLE 13 Statistical Analysis of Severity of Red Pulp Atrophy in the Spleen of Male Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ (Combination Groups Only) | Severity^b^
Dose^a^ (Combination Groups Only) | Mean^c^ | S.E.
200 + 0 | 0.000 | 0.000
200 + 300 | 0.000 | 0.000
200 + 1,500 | 0.000 | 0.000
200 + 3,000 | *0.600 | 0.306
| Trend^d^ + (P=0.017)
| Test Used^e^ Dunn
400 + 0 | 0.000 | 0.000
400 + 300 | 0.000 | 0.000
400 + 1,500 | 0.000 | 0.221
400 + 3,000 | *0.700 | 0.367
| Trend^d^ + (P=0.0171)
| Test Used^e^ Dunn

a AZT + pyrazinamide in mg/kg per day

b Severity grade is presented as mean severity for all mice in group, including those with no lesion (0=normal, 1=minimal, 2=mild, 3=moderate, and 4=marked), and standard error (S.E.)

c n=10

d Direction and significance of trend (Jonckheere’s test)

e Multiple comparisons test comparing dose group to control group

* Significantly different from the control group (P≤0.05)

** Significantly different from the control group (P≤0.01)

### Other Lesions

Necrosis of various lymphoid tissues (spleen, lymph nodes, thymus) was seen in several male mice, most of which either died or underwent moribund sacrifice. All of these mice had received 3,000 mg/kg pyrazinamide either alone or in combination with AZT. The lymphoid tissue necrosis was considered a nonspecific stress-induced change rather than a direct drug-related lesion.

Lesions involving the bone, which was not required to be routinely examined microscopically, occurred in several male mice. The bone lesions usually appeared at necropsy as nodules or focal enlargements on the ventral aspect of the thoracic vertebrae or on the ribs near their junction with the thoracic vertebrae. Microscopically, these lesions appeared usually as hyperostosis or cartilaginous metaplasia with occasional associated fibrosis or necrosis. Although these changes were not seen in any control group mice, there was no evidence of a treatment-related pattern, and these lesions were believed to be secondary to the gavage procedure. Other lesions, such as hemorrhage, necrosis, and inflammation, occurred in a variety of tissues in a random pattern and were not believed to be associated with the test articles.

## Sperm Function Evaluation

Four of the male parameters were affected by treatment (Table 14). Administration of 200 or 400 mg/kg AZT alone resulted in a dose-related increase in left caudal weights that was statistically (P≤0.05) significant at the 200 mg/kg level. Mild elevations in caudal weight were not believed to be biologically significant.

A statistically significant decrease (P≤0.01) in epididymal sperm motility also occurred in the group treated with 200 mg/kg AZT. This finding was not considered to be biologically significant, as a dose-related pattern was not evident.

A decrease in mean left testicular weight occurred in the group treated with 3,000 mg/kg pyrazinamide alone. The mean left testicular weight was approximately 12% (0.1031 grams; P≤0.01) lower than the mean (0.1257 grams) in the control group.

For spermatid heads per gram of testis, there was a significant interaction (increase in counts) of both AZT and pyrazinamide (P≤0.05), indicating that the dose response relationship of AZT differs across doses of pyrazinamide. This interaction was not considered to have a negative impact on reproductive capacity. No other interaction effects occurred.

Table 14 Summary of Reproductive Tissue Evaluations in Male Swiss CD-1® Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Left Caudal Weight (g) | Left Testicular Weight (g) | Epididymal Sperm Motility (%) | Spermatid Heads Per Gram of Testis · 10^7b^
0 + 0 | 0.0177 ± 0.0008 | 0.1257 ± 0.0049 | 79.57 ± 2.40 (9) | 15.58 ± 0.44
200 + 0 | 0.0196 ± 0.0008^c^ | 0.1214 ± 0.0052 | 58.38 ± 6.65 (9)^e^ | 16.67 ± 0.70
400 + 0 | 0.0202 ± 0.0013 | 0.1280 ± 0.0044 | 74.20 ± 5.80 (9) | 14.60 ± 0.44
0 + 300 | 0.0180 ± 0.0007 | 0.1227 ± 0.0039 | 74.45 ± 4.75 | 15.95 ± 0.42
0 + 1,500 | 0.0184 ± 0.0011 | 0.1206 ± 0.0066 | 72.16 ± 4.16 | 15.11 ± 0.64
0 + 3,000 | 0.0182 ± 0.0008 (9) | 0.1031 ± 0.0026 (9)^d^ | 69.54 ± 6.53 (8) | 15.18 ± 0.38 (9)
200 + 300 | 0.0197 ± 0.0011^c^ | 0.1293 ± 0.0047 | 54.10 ± 8.11^e^ | 15.55 ± 0.76
200 + 1,500 | 0.0192 ± 0.0007^c^ | 0.1188 ± 0.0042 | 70.68 ± 2.40 (9)^e^ | 15.23 ± 0.46
200 + 3,000 | 0.0225 ± 0.0039 (8)^c^ | 0.1090 ± 0.0039 (8)^d^ | 58.64 ± 8.86 (7)^e^ | 16.88 ± 0.49 (8)
400 + 300 | 0.0182 ± 0.0009 | 0.1155 ± 0.0041 | 68.58 ± 5.12 (9) | 15.72 ± 0.31
400 + 1,500 | 0.0195 ± 0.0011 | 0.1181 ± 0.0062 | 64.57 ± 5.82 (9) | 15.91 ± 0.49
400 + 3,000 | 0.0212 ± 0.0008 (8) | 0.1137 ± 0.0056 (8)^d^ | 57.78 ± 7.94 (8) | 16.86 ± 0.67 (8)

Note: All findings presented as mean value ± standard error; n=10 unless otherwise noted.

a AZT + pyrazinamide in mg/kg per day

b Significant interaction of both AZT and pyrazinamide (P≤0.05) indicating the dose response relationship of AZT differs across doses of pyrazinamide

c P≤0.05 compared to 0 + 0 (control) group by Williams’ or Dunnett’s test when collapsed over levels of pyrazinamide exposure

d P≤0.01 compared to 0 + 0 (control) group when collapsed over levels of AZT exposure

e P≤0.01 compared to 0 + 0 (control) group when collapsed over levels of pyrazinamide exposure

## Natural Delivery Data

The administration of AZT, pyrazinamide, or any combination of AZT and pyrazinamide did not affect the incidence of pregnancy (determined by the presence of a vaginal plug) in female-B mice (Table 15). Administration of 400 mg/kg AZT + 3,000 mg/kg pyrazinamide resulted in a marked decline (P≤0.01) in the number of pregnant female-B mice that delivered litters (Table 15). Of the mice that were pregnant in this group, 26.7% (4/15) delivered litters. The low number of delivered litters was not associated with inadequate implantation sites (Table 16).

Administration of 3,000 mg/kg pyrazinamide alone or in combination with AZT resulted in a slight increase in the duration of gestation (Table 16). Duration of gestation for the control group averaged 19.9 days. Respective mean durations of gestation for female-B mice treated with 3,000 mg/kg pyrazinamide, 200 mg/kg AZT + 3,000 mg/kg of pyrazinamide, and 400 mg/kg AZT + 3,000 mg/kg pyrazinamide were approximately 20.6 (P≤0.01), 20.5 (P≤0.05), and 20.5 days.

TABLE 15 Occurrence of Pregnancy in Female-B Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Number Assigned | Number (%) Pregnant | Number (%) Delivered
0 + 0 | 15 | 15 (100) | 15 (100)
200 + 0 | 15 | 14 (93.3) | 14 (100)
400 + 0 | 15 | 14 (93.3) | 14 (100)
0 + 300 | 16 | 14 (87.5) | 13 (92.8)
0 + 1,500 | 16 | 14 (87.5) | 13 (92.8)
0 + 3,000 | 16 | 14 (87.5) | 13 (92.8)
200 + 300 | 16 | 12 (75.0) | 11 (91.7)
200 + 1,500 | 16 | 16 (100) | 16 (100)
200 + 3,000 | 16 | 15 (93.8) | 13 (86.7)
400 + 300 | 16 | 13 (81.2) | 13 (100)
400 + 1,500 | 16 | 13 (81.2) | 13 (100)
400 + 3,000 | 16 | 15 (93.8) | 4 (26.7)^**^

a AZT + pyrazinamide in mg/kg per day

** P≤0.01 compared to 0 + 0 (control) group by the Cochran-Armitage and Fisher’s exact tests

TABLE 16 Summary of Natural Delivery Litter Data for Female-B Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Litter Size (Mean ± SD^b^) | Implantation Sites (Mean ± SD^b^) | Duration of Gestation (Mean ± SD^b^) | Dams with Stillborn Pups (% of Dams that Delivered)
0 + 0 | 12.5 ± 1.2 | 13.3 ± 1.0 | 19.9 ± 0.2 | 1 (6.7)
200 + 0 | 12.8 ± 1.2 | 13.6 ± 0.9 | 19.8 ± 0.4 | 0 (0.0)
400 + 0 | 10.5 ± 3.3 | 11.6 ± 3.7 | 20.1 ± 0.5 | 2 (14.3)
0 + 300 | 11.6 ± 1.7 | 12.4 ± 1.2 | 19.9 ± 0.3 | 0 (0.0)
0 + 1,500 | 11.4 ± 2.8 | 12.7 ± 2.9 | 20.0 ± 0.4 | 1 (7.7)
0 + 3,000 | 10.0 ± 3.5 | 11.3 ± 3.3 | 20.6 ± 0.6^**^ | 1 (7.7)
200 + 300 | 12.4 ± 2.2 | 13.7 ± 1.6 | 20.2 ± 0.4 | 0 (0.0)
200 + 1,500 | 11.3 ± 2.0 | 12.4 ± 1.0+ | 20.1 ± 0.3 | 2 (12.5)
200 + 3,000 | 9.2 ± 4.1^*^+ | 13.6 ± 1.4 | 20.5 ± 0.5^*^+ | 5 (38.5)+
400 + 300 | 10.7 ± 2.0 | 11.5 ± 1.7^*^ | 20.0 ± 0.0 | 0 (0.0)
400 + 1,500 | 8.9 ± 3.9^*^ | 12.2 ± 2.2 | 20.3 ± 0.6 | 3 (23.1)
400 + 3,000 | 8.7 ± 4.9 | 14.0 ± 0.8 | 20.5 ± 0.6 | 2 (50.0)

Dose^a^ | Mean Live Litter Size (Mean ± SD^b^) | Pups Dying on Days 1–4/Total Alive on Day 1 (%) | Cumulative Survival (Live Litter Size on Day 4/Day 0) | Live Litter Size at Weighing (Day 4) (Mean ± SD^b^)
0 + 0 | 12.3 ± 1.1 | 0/185 (0.0) | 12.3/12.3 | 12.3 ± 1.1
200 + 0 | 12.8 ± 1.2 | 1/164 (0.6) | 12.5/12.8 | 12.5 ± 1.0
400 + 0 | 10.1 ± 3.6 | 10/139 (7.2)^**^ | 9.2/10.1 | 9.2 ± 3.8
0 + 300 | 11.6 ± 1.7 | 2/135 (1.5) | 11.1/11.6 | 11.1 ± 2.0
0 + 1,500 | 11.2 ± 2.9 | 6/145 (4.1)^*^ | 10.7/11.2 | 10.7 ± 3.0
0 + 3,000 | 9.7 ± 3.9 | 1/101 (1.0) | 9.1/9.7 | 9.1 ± 3.8
200 + 300 | 12.3 ± 2.3 | 4/135 (3.0) | 11.9/12.3 | 11.9 ± 2.1
200 + 1,500 | 11.1 ± 2.1 | 6/178 (3.4)^*^ | 10.8/11.1 | 10.8 ± 2.5
200 + 3,000 | 8.5 ± 3.7^**,++^ | 19/98 (19.4)^**,++^ | 7.2/8.5^**,++^ | 8.8 ± 2.3^**,++^
400 + 300 | 10.6 ± 2.1 | 2/138 (1.4)− | 10.5/10.6^*^ | 10.5 ± 2.0^*^
400 + 1,500 | 8.6 ± 4.2 | 10/112 (8.9)^**^ | 7.8/8.6^**^ | 7.8 ± 4.0^**^
400 + 3,000 | 6.7 ± 5.1 | 3/9 (33.3)^**^ | 2.0/6.7 | 6.0^c^

a AZT + pyrazinamide in mg/kg per day

b SD=standard deviation

c Value reported for only one dam (excludes values for one dam with no surviving pups and one dam with 11 pups found drowned on day 4).

* P≤0.05 compared to 0 + 0 (control) group by the Cochran-Armitage and Fisher’s exact tests (Dams with Stillborn Pups and Pups Dying on Days 1–4) or by Dunn=s test (all other parameters)

** P≤0.01 compared to 0 + 0 (control) group

+ P≤0.05 compared to 200 + 0 group

++ P≤0.01 compared to 200 + 0 group

− P≤0.05 compared to 400 + 0 group

The percentage of dams with stillborn pups was increased in female-B groups treated with AZT in combination with the highest dose of pyrazinamide (Table 16). Compared to the group treated with 200 mg/kg AZT alone, which did not have stillborn pups, administration of 200 mg/kg AZT + 3,000 mg/kg pyrazinamide resulted in 5/13 (38.5%; P≤0.05) dams with stillborn pups. For the group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide, 2/4 (50%) dams had stillborn pups. This value was not statistically significant (P>0.05) because of the low number of dams that delivered litters. None of the dams in any of the female-B treatment groups that delivered had all stillborn pups.

Treatment with higher combinations of AZT and pyrazinamide appeared to have a negative impact on litter size and live pups per litter (live litter size) on postnatal day 0. Compared to the control group, which averaged 12.5 pups per litter (Table 16), significant declines (P≤0.05) in litter size occurred in female-B groups treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide or 400 mg/kg AZT + 1,500 mg/kg pyrazinamide. Respective mean litter sizes for these groups were 9.2 (P≤0.05) and 8.9 (P≤0.05) pups per litter. Although not statistically significant because of the low number of dams that delivered (4/15, 26.7%), the group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide had an average of 8.7 pups per litter on day 0. In general, the average number of liveborn pups per litter on day 0 (Table 16) paralleled the average litter size on day 0. Compared to the control group, which had 12.3 live pups per litter, the female-B group treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide had 8.5 (P≤0.01) live pups per litter. Although not statistically significant (P≥0.05) when compared to the vehicle controls, the group treated with 400 mg/kg AZT + 3,000 mg/kg pyrazinamide averaged 6.7 pups per litter on day 0.

The percentage of pups dying on days 1 through 4 of the lactation period (Table 16) increased in a treatment-related pattern. For the group treated with 1,500 mg/kg pyrazinamide alone, 4.1% (P≤0.05) of the pups died. For the group treated with 400 mg/kg AZT alone, 7.2% (P≤0.01) of the pups died. Combination therapy resulted in an increase in the number of deaths in a dose-dependent pattern. For the female-B groups treated with 200 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide, 3.4% (P≤0.05) and 19.4% (P≤0.01) of the pups, respectively, died. For the groups treated with 400 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide, 8.9% (P≤0.01) and 33.3% (P≤0.01) of the pups died. None of the pups in the control group died.

Cumulative survival and live litter size at weighing (Table 16) declined in a treatment-related pattern. Although not statistically significant (P>0.05) when compared to the control group, which had an average of 12.3 pups per litter on day 4 of lactation, the mean litter size in the female-B group treated with 400 mg/kg AZT alone was 9.2 pups per litter. Similar declines occurred in groups treated with 1,500 or 3,000 mg/kg pyrazinamide alone, these groups having 10.7 and 9.1 pups per litter, respectively. Combination therapy exaggerated the declines in litter size on day 4. For the female-B group treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide, the mean litter size on day 4 was 7.2 (P≤0.01) pups per litter. For the groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective means for live litter size on day 4 were 10.5 (P≤0.05), 7.8 (P≤0.01), and 2.0 pups/litter. Similar treatment-related declines occurred in live litter size at the time of weighing on day 4.

Administration of 400 mg/kg AZT alone and 3,000 mg/kg pyrazinamide alone caused slight declines in pup body weight per litter on lactation day 0. Compared to litters in the control group, with pups weighing an average of 1.7 ± 0.1 grams, mean pup body weights for both of these two groups were 1.6 ± 0.2 grams. Further decreases in pup body weight occurred with combination therapy (Figure 11). For the group treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide, the mean pup body weight on day 0 was approximately 18% (1.4 ± 0.2 grams; P≤0.01) lower than the mean (1.7 ± 0.1 grams) in the controls. For the groups treated with 400 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide, respective mean pup weights were approximately 12% (1.5 ± 0.1 grams; P≤0.05) and 30% (1.2 ± 0.2 grams; P≤0.01) lower than the mean (1.7 ± 0.1 grams) in the controls. These treatment-related trends continued during the lactation period on days 1 through 4. On lactation day 1, respective mean pup body weights in groups treated with 200 or 400 mg/kg AZT + 3,000 mg/kg pyrazinamide were approximately 21.0% (1.5 ± 0.2 grams; P≤0.01) and 21.0% (1.5 ± 0.1 grams) lower than the mean (1.9 ± 0.1 grams) in the control group. On lactation day 4, respective mean pup body weights in groups treated with 200 or 400 mg/kg AZT + 3,000 mg/kg pyrazinamide were approximately 26.6% (2.2 ± 0.3 grams) and 33.3% (2.0 ± 0.0 grams) lower than the mean (3.0 ± 0.3 grams) in the control group.

FIGURE 11 Mean Body Weights per Litter for Pups of Female-B Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

(LD = Lactation Day; mean pup weight/litter include only values for litters in which pups survived to LD 4)

## Caesarean Section Data

Administration of AZT alone (200 or 400 mg/kg) and pyrazinamide alone (300, 1,500, or 3,000 mg/kg) had no impact on the pregnancy rate of female-A mice (Table 17). Combination therapy resulted in a dose-related decline in the incidence of pregnancy. The pregnancy rate (percent of dams plugged) was 30% (6/20; P≤0.01) in the female-A group treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide. For the female-A groups treated with 400 mg/kg AZT + 1,500 or 3,000 mg/kg pyrazinamide, respective pregnancy rates were 35% (7/20; P≤0.01) and 20% (4/20; P≤0.01). In general, the number of female-A mice caesarean-sectioned in each treatment group paralleled the number pregnant.

TABLE 17 Occurrence of Pregnancy in Female-A Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Number Pregnant (%)^b^ | Number Caesarean-Sectioned^c^
0 + 0 | 16 (80) | 14
200 + 0 | 19 (95) | 18
400 + 0 | 18 (90) | 18
0 + 300 | 17 (85) | 16
0 + 1,500 | 18 (90) | 17
0 + 3,000 | 18 (90) | 17
200 + 300 | 15 (75) | 15
200 + 1,500 | 14 (70)^+^ | 14
200 + 3,000 | 6 (30)^**,++^ | 5
400 + 300 | 19 (95) | 17
400 + 1,500 | 7 (35)^**,−^ | 7
400 + 3,000 | 4 (20)^**,−^ | 4

a AZT + pyrazinamide in mg/kg per day

b n=20. Pregnancy was determined by the presence of a vaginal plug.

c Values were excluded for dams that delivered, died, or were Caesarean-sectioned prior to scheduled sacrifice.

** P≤0.01 compared to 0 + 0 (control) group by the Cochran-Armitage and Fisher=s exact tests

+ P≤0.05 compared to 200 + 0 group

++ P≤0.01 compared to 200 + 0 group

− P≤0.01 compared to 400 + 0 group

Litter size and the number of live fetuses per litter were not altered by pyrazinamide alone (Table 18). Administration of AZT alone caused a reduction in live litter size. Compared to the control group, with an average of 10.9 live fetuses per litter, female-A groups treated with 200 or 400 mg/kg AZT alone had 8.3 and 3.9 (P≤0.01) live fetuses per litter, respectively. Live litter size was also reduced in female-A groups treated with higher combinations of AZT and pyrazinamide. The group treated with 200 mg/kg AZT + 3,000 mg/kg pyrazinamide averaged 1 (P≤0.05) live fetus per litter. For the female-A groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, the average numbers of live fetuses per litter, respectively, were 4.6 (P≤0.01), 4.7 (P≤0.05), and 1.8 (P≤0.05).

TABLE 18 Summary of Caesarean-Sectioning Litter Data for Female-A Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Corpora | Implantation s | Litter Size | Live Fetuses | | Resorptions
Dose^a^ | Lutea | Implantation s | Mean ± SD^b^ | n | Mean ± SD^b^ | n | Mean ± SD^b^
0 + 0 | 12.1 ± 3.3 | 11.4 ± 3.2 | 10.9 ± 3.0 | 153 | 10.9 ± 3.0 | 6 | 0.4 ± 0.5
200 + 0 | 13.0 ± 2.7 | 11.3 ± 3.4 | 8.4 ± 4.0 | 150 | 8.3 ± 4.0 | 52 | 2.9 ± 2.7^**^
400 + 0 | 12.5 ± 3.1 | 9.3 ± 9.3 | 3.9 ± 3.4^**^ | 71 | 3.9 ± 3.4^**^ | 96 | 5.3 ± 3.9^**^
0 + 300 | 11.1 ± 3.9 | 10.6 ± 3.5 | 9.8 ± 4.3 | 157 | 9.8 ± 4.3 | 12 | 0.8 ± 1.5
0 + 1,500 | 12.0 ± 4.2 | 10.6 ± 3.5 | 9.4 ± 3.3 | 146 | 8.6 ± 3.9 | 21 | 1.2 ± 1.3
0 + 3,000 | 14.0 ± 2.3 | 13.2 ± 2.4 | 11.6 ± 2.6 | 188 | 11.0 ± 2.5 | 28 | 1.6 ± 1.1^*^
200 + 300 | 12.3 ± 3.4 | 9.8 ± 4.1 | 7.7 ± 4.0 | 114 | 7.6 ± 4.0 | 32 | 2.1 ± 1.3^**^
200 + 1,500 | 12.4 ± 3.3 | 11.6 ± 3.0 | 8.6 ± 3.9 | 118 | 8.4 ± 3.8 | 42 | 3.0 ± 2.5^*^
200 + 3,000 | 9.0 ± 5.1 | 5.8 ± 2.8 | 1.0 ± 1.4^*^+ | 5 | 1.0 ± 1.4^*^+ | 24 | 4.8 ± 1.6^**^
400 + 300 | 11.7 ± 3.1 | 10.5 ± 3.5 | 4.6 ± 4.6^**^ | 78 | 4.6 ± 4.6^**^ | 100 | 5.9 ± 4.4^**^
400 + 1,500 | 11.6 ± 3.2 | 9.8 ± 4.2 | 4.7 ± 3.5 | 33 | 4.7 ± 3.5^*^ | 36 | 5.1 ± 3.1^**^

a AZT + pyrazinamide in mg/kg per day

b Standard deviation

* P≤0.05 compared to 0 + 0 (control) group by Dunn=s test

** P≤0.01 compared to 0 + 0 (control) group

+ P≤0.05 compared to 200 + 0 group

No significant (P<0.05) differences were noted between the number of corpora lutae or implantations per litter (Table 18) when treated female-A groups were compared to untreated controls.

An increase in the mean number of resorptions (Table 18) occurred in female-A groups treated with AZT alone, pyrazinamide alone, and combinations of AZT and pyrazinamide. For the female-A groups treated with 200 or 400 mg/kg AZT alone, the mean numbers of resorptions were 2.9 (P≤0.01) and 5.3 (P≤0.01) per dam, respectively. For the group treated with 3,000 mg/kg pyrazinamide alone, 1.6 (P≤0.05) resorptions per dam occurred. In general, the number of resorptions in groups treated with combination therapy increased in a dose-dependent pattern. For the female-A groups treated with 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, the mean numbers of resorptions were 2.1 (P≤0.01), 3.0 (P≤0.01), and 4.8 (P≤0.01), respectively. For groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, 5.9 (P≤0.01), 5.1 (P≤0.01), and 10.2 (P≤0.05) resorptions per dam, respectively, occurred.

Treatment-related declines in average fetal weight per litter (Table 19) occurred in female-A groups receiving AZT alone, pyrazinamide alone, and combinations of AZT and pyrazinamide. Respective mean fetal weight per litter for groups treated with 200 or 400 mg/kg AZT alone were approximately 14% (1.25 grams; P≤0.01) and 21% (1.14 grams; P≤0.01) lower than the mean (1.45 grams) in the control group. For the group treated with 3,000 mg/kg pyrazinamide alone, the mean fetal weight per litter was approximately 30% (1.01 grams; P≤0.01) lower than the control-group mean (1.45 grams). Further declines with a dose-dependent pattern occurred with combination therapy. For the female-A groups receiving 200 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean fetal weights per litter were approximately 17% (1.21 grams; P≤0.01), 23% (1.11 grams; P≤0.01) and 44% (0.81 grams) lower than the mean (1.45 grams) in the control group. For the groups treated with 400 mg/kg AZT + 300, 1,500, or 3,000 mg/kg pyrazinamide, respective mean fetal weights per litter were approximately 24% (1.10 grams; P≤0.01), 32% (0.99 grams; P≤0.01), and 48% (0.76 grams) lower than the mean (1.45 grams) in the control group.

TABLE 19 Body Weights of Fetuses from Female-A Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Mean Fetal Weight (g)
Dose^a^ | Mean ± SD^b^
0 + 0 | 1.45 ± 0.16
200 + 0 | 1.25 ± 0.13^**^
400 + 0 | 1.14 ± 0.18^*^
0 + 300 | 1.47 ± 0.14
0 + 1,500 | 1.34 ± 0.10
0 + 3,000 | 1.01 ± 0.07^**^
200 + 300 | 1.21 ± 0.19^**^
200 + 1,500 | 1.11 ± 0.14^**^
200 + 3,000 | 0.81 ± 0.10
400 + 300 | 1.10 ± 0.05^**^
400 + 1,500 | 0.99 ± 0.12^**^
400 + 3,000 | 0.76 ± 0.25

a AZT + pyrazinamide in mg/kg per day

b Standard deviation

* P≤0.05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P≤0.01 compared to 0 + 0 (control) group

## Gross External Alterations (Female-A Litters)

Administration of AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide did not result in significant (P≤0.05) increases in the fetal or litter incidence of external abnormalities (Table 20). Although the frequency of external alterations was greater in groups treated with pyrazinamide alone, none of the abnormalities occurred in a dose-dependent pattern and none were statistically significant (P>0.05) when compared to the control group.

TABLE 20 Summary of Gross Alterations in Fetuses from Female-A Swiss CD-1^®^ Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Observation | Dose^a^ | Litter Incidence^b^ | Fetal Incidence^c^
Head, exencephaly | 0 + 1,500 | 2 (13.3) | 2 (1.4)
| 0 + 3,000 | 3 (17.6) | 3 (1.6)
| 400 + 300 | 1 (9.1) | 1 (1.3)
Head, encephalocele | 0 + 3,000 | 1 (5.9) | 1 (0.5)
Head, hematoma | 0 + 1,500 | 1 (6.7) | 1 (0.7)
Eyes, open | 0 + 3,000 | 1 (5.9) | 1 (0.5)
Ears, low set | 0 + 3,000 | 1 (5.9) | 1 (0.5)
Palate, cleft | 0 + 3,000 | 1 (5.9) | 1 (0.5)
| 200 + 1,500 | 2 (15.4) | 2 (1.7)
Tongue, protrudes | 0 + 3,000 | 1 (5.9) | 1 (0.5)
Body, edema | 400 + 3,000 | 1 (50.0) | 1 (14.3)
Limbs, clubfoot | 0 + 0 | 3 (21.4) | 6 (3.9)
| 0 + 300 | 1 (6.2) | 1 (0.6)
| 0 + 1,500 | 1 (6.7) | 2 (1.4)
| 0 + 3,000 | 1 (5.9) | 1 (0.5)
| 200 + 0 | 2 (11.8) | 2 (1.3)
Tail, hematoma | 0 + 0 | 1 (7.1) | 1 (0.6)

a AZT + pyrazinamide in mg/kg per day

b Number of litters with the observation followed by the percent (number of litters with the observation/number of litters evaluated).

c Number of fetuses with the observation followed by the percent (number of fetuses with the observation/number of fetuses evaluated; excludes dead fetuses).