# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; Lot 7434-36-05 RTI) was manufactured by Raylo Chemicals (Edmonton, Alberta) and Burroughs Wellcome (Research Triangle Park, NC) and supplied as a powder. Pyrazinamide (Lot 7494 40-03 RTI) was manufactured by Aldrich Chemical Co. (Milwaukee, WI) and supplied as a powder. Identification of both compounds was confirmed by infrared and nuclear magnetic resonance spectroscopy. The purity of both AZT and pyrazinamide was determined by high-performance liquid chromatography to be greater than 99%.

The control article was an aqueous solution containing 0.5% methylcellulose. The methylcellulose (Lot 876672) was procured from Fisher Scientific Co. (Pittsburgh, PA).

## Dose Formulations

The test articles were combined, singly or in combination, with the control article. The dose formulations were then stirred until visually homogeneous. Stability studies at refrigeration and room temperatures indicated a stability for AZT/pyrazinamide formulations of at least 23 days when stored refrigerated or at ambient temperature. Dose formulations for this study were stored refrigerated and protected from light and were used within 20 days of mixing.

Samples at each dose concentration from the initial mix were analyzed for concentration prior to dosing. Residual formulations taken from the same mix after dosing were also analyzed. Prior to dosing, the found concentrations of AZT ranged from 94.5% to 103% of the target concentrations. The found concentrations of pyrazinamide were 90.3% to 111% of the target concentrations. Found concentrations of the residual formulations ranged from 96.4% to 99.9% (AZT) and 95.3% to 111% (pyrazinamide) of the target concentrations.

At the first mix, samples taken from the top, middle, and bottom of selected formulations were analyzed in triplicate to determine homogeneity. Results from these analyses indicated that the formulations were homogeneous.

## Study Design

Male and female Swiss CD-1® mice were obtained from Charles River Laboratories, Inc., Raleigh, NC. The mice were separated by sex and group housed (five per cage) during quarantine before randomization; all mice were individually housed after randomization, except during cohabitation, when the animals were housed one male and two or three females per cage.

The mice were housed in polycarbonate cages with solid bottoms and sides. The cages were suspended on stainless steel racks and heat-treated hardwood chips were used as the contact bedding. Appropriate environmental conditions were maintained in the animal rooms throughout quarantine and testing.

At terminal sacrifice, blood samples were collected from five sentinel animals per sex from each animal room as part of the animal disease screening program. Results indicated that all animals were free of viral antibodies.

The basic premise for dose selection is that the high-dose level should induce some measurable evidence of toxicity (e.g., anemia, weight loss, target organ toxicity). In a number of studies conducted with this protocol, AZT at the doses selected (200 and 400 mg/kg per day) caused decreases in hematology parameters, increased resorptions, and decreased litter sizes (NIEHS, 1999). The human dose is 10 mg/kg per day (PDR, 1999). The selected doses were 20 times and 40 times human doses, but on a body surface area basis, the doses were close to 2 times and 4 times therapeutic dose (Freireich, et al., 1966).

The pyrazinamide doses selected were 300, 1,500, and 3,000 mg/kg per day. Grosset, et al. (1992) reported eradication of experimental tuberculosis in Swiss CD-1® mice with 150 mg of pyrazinamide/kg per day. In a previous reproductive/developmental and general toxicity study of pyrazinamide in Swiss CD-1® mice (NIEHS, 1997), dosages of pyrazinamide as high as 1,200 mg/kg per day did not result in significant toxicity. A subchronic toxicity study was conducted with pyrazinamide alone and in combination with AZT (Rao et al., 1998; NIEHS, 2000). For the B6C3F1 mice treated with 1,500 mg of pyrazinamide/kg per day alone, significant alterations in in life body weights, survival data, clinical signs, and hematology data were not evident at day 30 or at 13 weeks. Mild liver toxicity in the form of elevated liver weights and hepatocyte hypertrophy were evident at 13 weeks. A mild anemia was evident at both time points in mice treated with 1,500 mg of pyrazinamide/kg + 400 mg of AZT/kg. On a mg/kg per day basis, doses of pyrazinamide selected for the current study were 2, 10, and 20 times the therapeutic dose for experimental tuberculosis in mice (Grosset, et al., 1992). Evidence of mild hepatotoxicity was present at the end of the subchronic study; thus, liver weights and liver enzymes were evaluated.

A summary of the study design is presented in Table 2. The design of this study is a modification of a design published elsewhere (Harris et al., 1992). The oral route of administration was selected because it is the route used in humans, and the study was conducted in Swiss CD-1® mice because this strain is routinely used for reproductive/developmental toxicity evaluations. Doses of AZT alone, pyrazinamide alone, combinations of AZT and pyrazinamide, or the control article were administered by gavage as a single formulation in an aqueous solution containing methylcellulose. AZT was given at a concentration of 200 or 400 mg/kg per day. Pyrazinamide was given at a concentration of 300, 1,500, or 3,000 mg/kg per day. Total daily doses of 20 mL/kg were divided into two equal doses of 10 mL/kg given approximately 6 hours apart. Mice were divided into three groups as follows:

### Male Mice

Ten males were assigned to each dose group. Prior to dosing, male mice were cohabited with female-B mice on study days 0 through 4. Male mice were dosed beginning on study day 5 through the day prior to sacrifice. Males were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior. On study day 25 or 26, all male mice were weighed, and blood samples were obtained from the retroorbital sinus for hematology and clinical chemistry evaluations. The males were then euthanized with carbon dioxide, a necropsy was conducted, and the left testis and epididymis were collected and prepared for evaluation of sperm parameters as described in the Sperm Function Evaluation section.

### Female-A Mice

Twenty females were assigned to each dose group. Female-A mice were dosed beginning on study day 0 through the day prior to sacrifice. Male mice were cohabited with female-A mice on study days 9 to 13 to identify any effects of treatment on mating behavior, fertilization, implantation, or the initial stages of development. During cohabitation periods, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually and that day was designated as day 0 of gestation. At the end of the cohabitation period, all animals were housed individually. Prior to parturition on day 18 of presumed gestation (study days 28 to 32), all female-A mice were weighed, and blood samples were taken from the retroorbital sinus for hematology and clinical chemistry evaluations. The female-A mice were then euthanized with carbon dioxide, and necropsy and caesarean section evaluations were conducted. Live fetuses were removed, weighed, anesthetized on ice, and preserved in Bouin’s fixative; dead fetuses were also removed and preserved in Bouin’s fixative. The uteri of all sperm-negative females were examined for evidence of unsuccessful pregnancy and then press-plated between two heavy plates of glass to visualize implantation sites. Additional endpoints for all female-A mice included gravid uterine weight, number of implantation sites, resorptions, corpora lutea, and dead and live fetuses. For those dams that delivered pups prior to scheduled caesarean section, the live pups were weighed, sexed, and sacrificed; the uterus for each dam was press-plated, and the same parameters evaluated as for those dams sacrificed as scheduled.

### Female-B Mice

Twenty females were assigned to each dose group. Prior to dosing, the group B females were cohabited with males on study days 0 through 4. During the cohabitation period, the females were examined daily for the presence of a vaginal plug as an indicator of pregnancy. If a vaginal plug was evident, that female was housed individually and that day was designated as day 0 of gestation. At the end of the cohabitation period, sperm-negative female-B mice were euthanized with carbon dioxide and discarded without necropsy; all other animals were housed individually. Sperm-positive female-B mice were assigned evenly across dose groups prior to gestation day 6. Female-B mice were subsequently dosed during gestation days 6 through 15, during the fetal organogenesis period, to identify effects on fetal development. Residual effects on parturition and the beginning of lactation were also evaluated. Beginning on gestation day 16, the bedding material and feeders were no longer changed. From gestation day 17 until the litters were delivered, female-B mice were observed twice daily for evidence of labor or delivery. The day delivery was completed was determined to the nearest day and was designated as postnatal day 0. On postnatal days 0 and 1, dam body weights were recorded along with the number of live and dead pups, the number of male and female pups, the incidence of any external malformations, and live pup weights. Dead pups were discarded. On postnatal day 4, female-B mice, including any that did not deliver, were weighed and blood samples were collected from the retroorbital sinus for hematology determinations. These mice were then euthanized with carbon dioxide, and a complete necropsy was performed. The uterus was removed and press-plated. All pups were weighed, given a thorough external examination for lesions or malformations, and the sex was recorded. The pups were then euthanized with carbon dioxide and saved in Bouin’s fixative.

### Clinical Pathology

Blood was drawn at terminal sacrifice from all mice for hematology determinations and from male and female-A mice for clinical chemistry determinations. All blood samples were taken from the retroorbital sinus under CO2:O2 (70:30) anesthesia and were collected into tubes containing EDTA (hematology) or no anticoagulant (clinical chemistry). Animals were selected in random order for blood collection and samples were analyzed in the order collected. Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; leukocyte differentials; and erythrocyte and platelet morphologies were determined on whole blood using a Technicon H·1™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite™ Flow Cytometer. Blood smears were prepared to manually verify leukocyte differentials and morphologies if necessary, and platelet and erythrocyte morphological alterations were reported only in the raw data. Alanine aminotransferase, sorbitol dehydrogenase, alkaline phosphatase, aspartate aminotransferase, and total bile acids were determined using the Roche Cobas Fara™ automated analyzer.

### Sperm Function Evaluations

The left testis from each male was removed at necropsy and weighed. The left epididymis was weighed, then sperm samples were collected and mixed with modified Tyrode’s Solution on two prewarmed slides per animal. Slides were maintained at approximately 37° C and were viewed under a light microscope to assess sperm motility. The distal cauda of the epididymis was weighed then placed in a petri dish containing phosphate buffered saline, and the tissue was teased to release the contents. The final caudal epididymal sperm suspension was incubated for at least 15 minutes. An aliquot was then further diluted with saline solution and placed in a bath of hot water for greater than one minute to kill the sperm. Sperm density was determined using a hemocytometer. To quantify spermatogenesis, testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

A histopathologic examination was performed on tissues listed in Table 2. These tissues were cut (5-μm sections) and representative sections were mounted on glass microscope slides and stained with hematoxylin and eosin (testis stained with PAS). All tissues were examined microscopically by a veterinary pathologist and results were described using a standard nomenclature.

Table 2 Experimental Design and Materials and Methods for the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations in Swiss CD-1® Mice

Study Laboratory; Southern Research Institute, Birmingham, AL
Strain and Species; Swiss CD-1® mice
Animal Source; Charles River Laboratories, Inc., Raleigh, NC
Time Held Before Study; 10 days
Average Age When Study Began; 86 days
Date of Day 0; 2/3/95 for group 1 mice and 2/10/95 for group 2 mice
Date of First Dose; Males: day 5 (2/8/95 for group 1 and 2/15/95 for group 2); Females-A: day 0 (2/3/95 for group 1 and 2/10/95 for group 2); Females-B: gestation day 6 (2/10-14/95 for group 1 and 2/17-21/95 for group 2)
Date of Last Dose; Males: day prior to terminal sacrifice; Females-A: day prior to terminal sacrifice; Females-B: gestation day 15 (2/19-23/95 for group 1 and 2/26/95-3/2/95 for group 2)
Days of Cohabitation; Males and Females-A: days 9–13; Males and Females-B: days 0–4; When possible, 1 male and 2–3 females within the same dose group were housed together by consecutive animal number.
Necropsy Dates; Males: days 25–26 (2/28/95-3/1/95 for group 1 and 3/7-8/95 for group 2); Females-A: days 28–32 (gestation day 18; 3/3-7/95 for group 1 and 3/10-14/95 for group 2); Females-B: Postnatal day 4 or 5 (2/27/95-3/5/95 for group 1 and 3/6-10/95 for group 2); these dates were also days 24–28 of presumed gestation for sperm-positive mice that did not deliver. Sperm-negative mice were necropsied on day 5 (2/8/95 for group 1 and 2/15/95 for group 2) after cohabitation.
Average Age at Terminal Necropsy; Males: 111–112 days; Females-A: 114–118 days; Females-B: 110–116 days
Size of Study Groups; 10 males, 20 females-A, 20 females-B per dose group; each dose group divided into group 1 and group 2
Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups in random order. To more evenly distribute the number of successful matings, some female-B mice were reassigned at the end of the cohabitation period and prior to dosing.
Method of Animal Identification; Tail tattoo
Diet; NIH-07 pelleted feed (Zeigler Brothers, Inc., Gardners, PA), available ad libitum; fresh feed provided weekly or as needed
Water; Tap water (Birmingham, AL), available ad libitum via automatic watering system (Edstrom Industries, Inc., Waterford, WI)
Cages; Polycarbonate cages with solid bottoms and sides (Lab Products, Inc., Maywood, NJ); changed once weekly, except during delivery and lactation periods (gestation day 16 to termination) for female-B mice
Bedding; Heat-treated hardwood chips (Sani-Chips®, P.J. Murphy Forest Products Corporation, Montville, NJ); changed once weekly, except during delivery and lactation periods (gestation day 16 to termination) for female-B mice
Cage Filters; Remay® spun-bonded polyester (Andico, Birmingham, AL); changed once every 2 weeks
Racks; Stainless steel (Lab Products, Maywood, NJ); changed once every 2 weeks
Animal Room Environment; Temperature: 70.7° ± 0.9° F; Relative humidity: 43.7% ± 6.3%; Fluorescent light: 12 hours/day; Room air: minimum of 10 changes/hour
Doses; 0 mg AZT + 0 mg pyrazinamide per kg body weight per day; 0 mg AZT + 300 mg pyrazinamide per kg body weight per day; 0 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; 0 mg AZT + 3,000 mg pyrazinamide per kg body weight per day; 200 mg AZT + 0 mg pyrazinamide per kg body weight per day; 200 mg AZT + 300 mg pyrazinamide per kg body weight per day; 200 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; 200 mg AZT + 3,000 mg pyrazinamide per kg body weight per day; 400 mg AZT + 0 mg pyrazinamide per kg body weight per day; 400 mg AZT + 300 mg pyrazinamide per kg body weight per day; 400 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; 400 mg AZT + 3,000 mg pyrazinamide per kg body weight per day
Type and Frequency of Observation; Mortality/moribundity: twice daily; Clinical findings: once daily; Vaginal plugs: days 10–14 for females-A, days 1–5 for females-B; Body weights: days 3, 5, 9, 13, 17, 21, 23, and sacrifice for males; days 0, 4, 12, 16, 20, 23, 26, and sacrifice for females-A; gestation days 0, 8, 12, 15, and postnatal days 0, 1, and 4 for females-B; postnatal days 0, 1, and 4 for F1 pups.
Clinical Pathology; Hematology evaluations on all animals at terminal sacrifice; clinical chemistry evaluations on males and females-A at terminal sacrifice.
Sperm Function Evaluation; Conducted on all males at terminal sacrifice
Necropsy; Complete necropsies were performed on all breeder animals except sperm-negative females-B. The following were collected at necropsy, saved in formalin (testis saved in Bouin’s), and examined histopathologically: males - liver, kidney, lung, heart, spleen, thymus, mandibular and mesenteric lymph nodes, right testis, brain, bone marrow, and gross lesions; liver and right epididymis were weighed; females-A - liver and gross lesions; liver was weighed; females-B - no tissues; pups were examined only grossly at necropsy.

## Statistical Methods

Statistical comparisons were made for all groups against each AZT/vehicle control and the group administered the vehicle alone. Reported significance levels were P≤0.05 and P≤0.01. Proportion data (e.g., the incidences of pregnancy, resorption, death, and total resorption) for presumed pregnant mice were analyzed using the Cochran Armitage Test for a Linear Trend in Proportions (Snedecor and Cochran, 1967a) and Fisher’s exact test (Siegel, 1956). Paternal and maternal body weight evaluations were analyzed using Bartlett’s test of Homogeneity of Variances (Sokal and Rohlf, 1969a) and the Analysis of Variance (Snedecor and Cochran, 1967b). If the Analysis of Variance was significant and appropriate (i.e., it passed Bartlett’s test, P>0.05), then Scheffe’s test (Scheffe, 1953) was used to identify the statistical significance of individual groups. If the Analysis of Variance was not appropriate (P≤0.05), the Kruskal-Wallis test (Sokal and Rohlf, 1969b) was used; in cases where statistical significance occurred (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify the statistical significance of individual groups. These methods were also used to analyze fetal body weight and pup body weight (per litter), as well as all other evaluations involving continuous data. Observations for delivered and dead fetuses of the female-A dams and fetuses from female-A dams caesarean-sectioned on an estimated day 14 of gestation were excluded from fetal body weight summaries and statistical analyses. Data obtained at caesarean-sectioning and natural delivery were evaluated by the Kruskal-Wallis test (Sokal and Rolf, 1969b). In cases where statistical significance occurred (P≤0.05), Dunn’s (1964) method of multiple comparisons was used to identify statistical significance of individual groups.

For terminal body and organ weight data, group means and standard deviations and organ/body weight ratios were calculated. Mean terminal body weights, mean organ weights, and organ/body weight ratios for each treated group were compared to those of the control group by a two-tailed Student’s t-test for each sex. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and treated groups. The reported significance level was P≤0.05.

For clinical pathology data, group means and standard deviations were calculated and data were evaluated for significance using Dunnett’s (1955) test. Reported significance levels were P<0.05 and P<0.01.

Sperm evaluation data were analyzed using a two-way analysis of variance. If the interaction was not statistically significant, averages were taken for each compound over the levels of the second compound, and control and treated group means were compared using either Williams’ (1971, 1972) or Dunnett’s (1955) multiple comparison procedures. The choice between the two tests was based on the evidence of a dose-related trend in the data as assessed by Jonckheere’s test (1954). Williams’ test was applied if there was an indication of trend (P<0.01), and Dunnett’s test was used in the absence of a trend. Prior to analysis, the outlier test of Dixon and Massey (1951) was employed to detect extreme values, and those that were deemed implausible, due to error, or due to sickness from causes other than test-article toxicity were eliminated. The reported significance levels were P<0.05 and P<0.01.

For histopathology data, the presence of dose effects and interaction between AZT and pyrazinamide was assessed using methods of generalized linear models (Fahrmeir and Tutz, 1994). The dependent variables used were graded histopathological lesions indexed as 0 through 4. These indices were assumed to follow a multinomial distribution. A cumulative logit link function was used to relate dependent variables to treatment effects. AZT and pyrazinamide dose effects and their interactions were investigated by analysis of deviance (Jonckheere, 1954). Statistical significance of main and interaction effects was assessed using P values obtained from likelihood ratio tests (Dunn, 1964; Shirley, 1977).