# Introduction

Acquired immunodeficiency syndrome (AIDS) is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegle et al., 1981). The etiological agent of AIDS is a retrovirus that is now referred to as the human immunodeficiency virus (HIV) (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in life span (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss CD-1^®^ mice were dosed daily by gavage with AZT doses of 100, 250, 500, or 1,000 mg/kg for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematological results and included lymphoid depletion, reticuloendothelial hyperplasia in the spleen and thymus, and bone marrow hypocellularity.

In a 14-week study (NTP, 1999), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg of AZT/kg administered by gavage. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups were administered doses of 0, 50, 400, or 1,000 mg of AZT/kg twice daily for approximately 92 days and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical observation in AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle (Rao et al., 1998).

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose-proportional over the oral dose concentration range.

Standard teratology tests of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g or 76 times the antiviral ID_50_. Rabbits were dosed orally at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g or 50 times the antiviral ID_50_.

Female Wistar rats were dosed orally three times with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal weight gain, food consumption, hematological parameters, and growth or survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female C_3_H/He mice were exposed to 0, 0.25, 0.5, or 2.5 mg/mL of AZT in the drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Since AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992). As a result, the treatment of AIDS is increasingly one of combination therapy of anti-AIDS drugs and anti-infective drugs (Goldschmidt and Dong, 1992). Tuberculosis (TB) is one of the opportunistic diseases leading to mortality in AIDS patients (Nolan, 1992), and the spread of the HIV virus is one of the factors contributing to the resurgence of TB and resistant strains of the microorganisms that cause TB (Humma, 1996). The prevalence of TB in HIV-infected individuals is high and the largest increases in TB nationally and internationally have occurred in urban areas that have a high percentage of HIV-infected individuals (Blanchard, 1996).

AIDS patients with TB receive combination therapy with AZT and antituberculosis drugs (CDC, 1998a). Treatment for TB involves combination therapy with multiple antibacterial agents in order to eliminate the strains of organisms inducing the disease, including those resistant to isoniazid, the primary drug used in treating TB. The standard regimen is isoniazid (300 mg/day), rifampicin (600 mg/day; 450 mg/day for persons weighing less than 50 kg), and pyrazinamide (20 to 30 mg/kg per day) for the first 2 months of treatment. Isoniazid and rifampicin are continued for another 7 months, for a total therapy duration of 9 months (CDC, 1987; Barnes et al., 1991). For patients intolerant of rifampicins, combinations of isoniazid, streptomycin, ethambutol, and pyrazinamide are used, and rifabutin is substituted for rifampicin in patients receiving antiretroviral protease inhibitors (CDC, 1998a). The inclusion of pyrazinamide in treatment regimens has made possible the shortening of therapy to 6 months (East and Central African/British Medical Research Council, 1986).

Pyrazinamide is an analogue of nicotinamide and is thought to be a pro-drug that requires deamidation by an endogenous mycobacterial enzyme, pyrazinamidase, to form pyrazinoic acid (Barry, 1997). Pyrazinoic acid is thought to be a toxic metabolite, but the precise cellular functions inhibited by this molecule are not known (Blanchard, 1996; Barry, 1997). Pyrazinamide appears to be effective in vivo against semidormant bacilli in acidic intracellular environments such as macrophages (Blanchard, 1996).

Pyrazinamide is well absorbed from the gastrointestinal tract, and it is widely distributed throughout the body. The oral administration of 1 gram produces plasma concentrations of about 45 μg/mL at 2 hours and 10 μg/mL at 15 hours. The drug is excreted primarily by renal glomerular filtration; urinary concentrations are 50 to 100 μg/mL for several hours after a single dose. Pyrazinamide is hydrolyzed to pyrazinoic acid and subsequently hydroxylated to 5-hydroxypyrazinoic acid, the major excretory product (Weiner and Tinker, 1972). Grossett et al. (1992) reported that 150 mg/kg pyrazinamide (considered to be a therapeutic dose) administered by gavage to female Swiss CD-1^®^ mice resulted in serum concentrations similar to those of humans receiving pyrazinamide therapy.

Injury to the liver is the most common and serious side effect of pyrazinamide. When a dose of 3 grams per day (40 to 50 mg/kg body weight) is orally administered, signs and symptoms of hepatic disease appear in about 15% of patients, with jaundice in 2% to 3% and death due to hepatic necrosis in rare instances (Mandel and Sande, 1990). Mild and transient elevations of plasma alanine and aspartate aminotransferases are the earliest abnormalities produced by the drug and occur approximately 2 weeks after initiation of therapy (Ramakrishnan et al., 1968). Baron and Bell (1974) have pointed out that such transient asymptomatic increases in the serum hepatic enzyme concentrations are also common during the early weeks of anti-TB chemotherapy with other drugs, and these usually return to normal without interrupting or altering the treatment and so are not clinically important.

In a review of the hepatotoxicity of antitubercular treatments in humans, pyrazinamide was referred to as a major hepatotoxin (Durand et al., 1996); however, the molecular mechanism for the toxicity of pyrazinamide has not been established. The author described two patterns of fulminant liver injury in patients receiving combinations of isoniazid, rifampicin, and pyrazinamide. The first pattern consists of an increase in serum transaminase activity within 15 days after initiation of treatment. This pattern is believed to be rifampicin-induced isoniazid hepatotoxicity and has a good prognosis. The second pattern consists of increased serum transaminase activity more than 1 month after start of treatment. This pattern may be related to pyrazinamide hepatotoxicity and has a poor prognosis. The frequency of hepatotoxicity with combination antitubercular treatments rose from approximately 0.5% in patients not receiving pyrazinamide to approximately 2% in patients receiving antitubercular treatments that included pyrazinamide.

Hepatotoxicity and nephrotoxicity occurred in male Wistar rats following the administration of 2.5 g/kg of pyrazinamide by gavage in 10% gum arabic (Zitkova et al., 1983). Bederka et al. (1975) have reported an LD_25_ for pyrazinamide in young adult female Swiss albino and Charles River mice (20 to 32 grams) of 705 mg/kg of body weight following intraperitoneal administration in dimethyl sulfoxide. The LD_50_ data for pyrazinamide reported in the Registry of Toxic Effects of Chemical Substances are as follows: mouse, intraperitoneal, 1,680 mg/kg; mouse, subcutaneous, 2,793 mg/kg (RTECS, 1983). No apparent hematological, reproductive, or developmental toxicity occurred in female Swiss CD-1^®^ mice administered 400, 800, or 1,200 mg pyrazinamide/kg body weight by oral gavage for 30 days (NIEHS, 1997). In a subchronic study (Rao et al., 1998; NIEHS, 2000), male and female B6C3F_1_ mice treated with 1,000 or 1,500 mg pyrazinamide/kg body weight by gavage developed increases in liver weights and increases in the incidence and severity of hepatocellular glycogen depletion. Significant alterations did not occur in hematology parameters or body weights.

Roman and Georgian (1977) studied the comparative cytogenetic effects of para-aminosalicylic acid sodium salt, pyrazinamide, and rifampicin in human peripheral blood cultures. The structural chromosomal lesions were randomly distributed between the different chromosome groups of the human karyotype; nearly 20% to 30% of affected cells had more than one lesion per metaphase. In the treatments with sodium para-aminosalicylate and pyrazinamide, the analysis of the frequencies of the cells carrying chromosomal aberrations and of the chromosomal lesion types indicated a dose-response correlation. The in vitro studies indicate a potential genetic hazard in the use of these drugs.

## Study Rationale

This study was conducted by the NIEHS as part of its program to evaluate the safety, in pregnant women and in the developing conceptus, of drugs used in the treatment of AIDS or the opportunistic infections accompanying AIDS. The effects on the motility and density of sperm were also evaluated. Tuberculosis is a common opportunistic infection of AIDS patients and is treated with numerous antibacterial compounds, including pyrazinamide, isoniazid, rifampicin, rifabutin, streptomycin, and ethambutol (CDC, 1998a). Considering the numerous antiretroviral agents currently recommended (CDC, 1998b), the potential for drug interactions is enormous. AZT and pyrazinamide are only two of numerous therapeutic compounds an AIDS patient with tuberculosis might receive. Animal reproduction studies have been conducted on AZT alone and on pyrazinamide alone, but not on the combinationtherapy of AZT plus pyrazinamide. Also, it is not known whether the combination therapy of AZT plus pyrazinamide can cause harm to the conceptus when administered to pregnant women or whether the treatment can affect reproductive capacity. To facilitate the screening of chemicals for reproductive and developmental toxicity, the National Toxicology Program has developed a protocol that combines aspects of other studies designed for this purpose (Morrissey et al., 1989; Harris et al., 1992). Because the liver has been shown to be a target organ of pyrazinamide in humans, liver enzyme determinations and evaluation of liver weight and pathology were included.

The objective of this study was to obtain controlled laboratory data on the reproductive and developmental toxicity of AZT and pyrazinamide combination therapy. Adult mice were evaluated for clinical signs, body weights, sperm function evaluations, clinical pathology evaluations (selected parameters due to limited amount of sample), and necropsy and histopathology evaluations for selected groups and tissues. Offspring were evaluated for viability, external abnormalities, and weight.