# APPENDIX B Clinical Pathology Results

TABLE B1 Hematology Data for Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations^a^

Male Mice

| WBC | RBC | HGB | HCT | MCV | MCH | PLT | RETIC | NEUT | LYMPH
| 10^3^/L | 10^6^/L | g/dL | % | fL | pg | 10^3^/L | 10^5^/L | 10^3^/L | 10^3^/L
0 + 0 mg/kg per day^b^
Mean | 6.19 | 9.37 | 15.3 | 45.1 | 48.2 | 16.4 | 932 | 5.0 | 1.00 | 4.77
SD | 1.260 | 1.346 | 2.17 | 6.86 | 2.10 | 0.77 | 274.2 | 0.57 | 0.395 | 0.827
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 0 mg/kg per day
Mean | 6.29 | 8.22 | 14.3 | 43.5 | 53.2^**^ | 17.5 | 1,147 | 5.4 | 1.52 | 4.37
SD | 3.121 | 1.062 | 1.80 | 4.41 | 3.86 | 0.89 | 290.7 | 1.39 | 1.772 | 1.642
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 0 mg/kg per day
Mean | 5.67 | 8.18 | 14.3 | 43.7 | 53.6^**^ | 17.5 | 1,129 | 6.5 | 5.67 | 8.18
SD | 1.279 | 1.096 | 1.96 | 5.21 | 3.25 | 0.69 | 208.9 | 1.49 | 1.279 | 1.096
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 300 mg/kg per day
Mean | 6.52 | 9.98 | 16.5 | 48.4 | 48.7 | 16.5 | 878 | 5.4 | 1.08 | 5.05
SD | 1.632 | 1.314 | 1.80 | 4.93 | 2.56 | 0.68 | 257.3 | 2.12 | 0.440 | 1.319
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 1,500 mg/kg per day
Mean | 7.35 | 9.73 | 16.0 | 47.1 | 48.5 | 16.4 | 1,059 | 5.2 | 1.61 | 5.24
SD | 2.457 | 1.034 | 1.82 | 4.76 | 2.05 | 0.71 | 137.2 | 1.22 | 0.800 | 1.960
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
0 + 3,000 mg/kg per day
Mean | 5.19 | 9.49 | 15.8 | 46.8 | 49.3 | 16.7 | 1,163 | 5.1 | 1.18 | 3.69
SD | 2.209 | 0.492 | 0.93 | 2.55 | 2.19 | 0.69 | 256.2 | 0.82 | 0.526 | 1.736
n | 10 | 9 | 9 | 9 | 9 | 9 | 9 | 9 | 9 | 9
200 + 300 mg/kg per day
Mean | 5.96 | 8.47 | 14.5 | 43.4 | 51.5 | 17.3 | 1,247 | 5.0 | 0.77 | 4.81
SD | 1.855 | 0.825 | 0.91 | 2.78 | 3.31 | 1.18 | 172.3 | 1.11 | 0.224 | 1.569
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 9 | 10 | 10
200 + 1,500 mg/kg per day
Mean | 5.21 | 8.14 | 14.3 | 43.2 | 53.2^**^ | 17.6 | 1,553^**^ | 5.2 | 1.18 | 3.62
SD | 1.804 | 0.854 | 1.45 | 4.25 | 2.40 | 0.66 | 210.8 | 1.12 | 0.598 | 1.320
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
200 + 3,000 mg/kg per day
Mean | 4.93 | 5.78^**^ | 9.6^**^ | 27.7^**^ | 47.7 | 16.6 | 1,978^**^ | 3.3 | 0.81 | 3.72
SD | 1.796 | 0.876 | 1.58 | 5.29 | 3.55 | 0.66 | 362.7 | 2.18 | 0.251 | 1.642
n | 8 | 8 | 8 | 8 | 8 | 8 | 8 | 8 | 8 | 8
400 + 300 mg/kg per day
Mean | 5.04 | 8.27 | 14.5 | 43.4 | 52.6^*^ | 17.5 | 1,172 | 4.9 | 0.60 | 4.07
SD | 1.875 | 1.097 | 1.98 | 5.58 | 1.95 | 0.69 | 202.1 | 0.84 | 0.270 | 1.528
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
400 + 1,500 mg/kg per day
Mean | 5.56 | 7.94^*^ | 13.9 | 41.9 | 52.9^**^ | 17.5 | 1,420^**^ | 5.0 | 1.19 | 3.92
SD | 1.758 | 0.466 | 1.10 | 3.44 | 3.52 | 0.96 | 266.1 | 1.21 | 0.636 | 1.504
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 9 | 10 | 10
400 + 3,000 mg/kg per day
Mean | 3.58 | 5.71^**^ | 9.6^**^ | 27.9^**^ | 48.5 | 16.7 | 1,824^**^ | 3.0 | 0.77 | 2.44
SD | 1.304 | 1.030 | 2.17 | 7.16 | 4.12 | 0.91 | 563.2 | 2.09 | 0.689 | 1.014
n | 8 | 8 | 8 | 8 | 8 | 8 | 8 | 7 | 8 | 8

a WBC=leukocytes, RBC=erythrocytes, HGB=hemoglobin, HCT=hematocrit, MCV=mean cell volume, MCH=mean cell hemoglobin, PLT=platelets, RETIC=reticulocytes, NEUT=neutrophils, LYMPH=lymphocytes

b AZT + pyrazinamide

* Significantly different (P<0.05) from the control by Dunnett’s test

** Significantly different (P<0.01) from the control by Dunnett’s test

Female-A Mice

| WBC | RBC | HGB | HCT | MCV | MCH | PLT | RETIC | NEUT | LYMPH
| 10^3^/L | 10^6^/L | g/dL | % | fL | pg | 10^3^/L | 10^5^/L | 10^3^/L | 10^3^/L
0 + 0 mg/kg per day^b^
Mean | 6.85 | 9.14 | 15.1 | 45.0 | 49.3 | 16.5 | 1,190 | 4.3 | 1.83 | 4.61
SD | 2.915 | 0.664 | 0.98 | 2.35 | 2.32 | 0.77 | 290.7 | 1.27 | 1.410 | 1.622
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
200 + 0 mg/kg per day
Mean | 5.95 | 7.88^**^ | 14.5 | 44.4 | 56.4^**^ | 18.4^**^ | 1,319 | 4.0 | 1.43 | 4.23
SD | 1.311 | 0.644 | 1.12 | 3.56 | 3.09 | 0.86 | 248.4 | 1.13 | 0.642 | 0.881
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
400 + 0 mg/kg per day
Mean | 5.96 | 7.62^**^ | 14.4 | 44.4 | 58.3^**^ | 18.8^**^ | 1,378 | 4.7 | 1.29 | 4.23
SD | 1.403 | 0.546 | 1.06 | 3.12 | 2.56 | 0.53 | 326.1 | 1.46 | 0.745 | 1.058
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
0 + 300 mg/kg per day
Mean | 6.95 | 8.80 | 14.9 | 44.2 | 50.3 | 17.0 | 1,251 | 4.6 | 1.91 | 4.65
SD | 2.304 | 0.891 | 1.33 | 3.91 | 1.69 | 0.68 | 288.8 | 1.64 | 1.237 | 1.683
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
0 + 1,500 mg/kg per day
Mean | 6.73 | 9.08 | 15.5 | 45.7 | 50.5 | 17.1 | 1,347 | 4.8 | 1.98 | 4.31
SD | 2.114 | 0.952 | 1.49 | 3.99 | 2.36 | 0.81 | 335.7 | 1.71 | 0.737 | 1.457
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
0 + 3,000 mg/kg per day
Mean | 7.07 | 9.33 | 16.3 | 48.4 | 52.0 | 17.4^*^ | 1,266 | 5.2 | 2.47 | 4.11
SD | 1.704 | 0.657 | 1.08 | 3.02 | 2.67 | 0.77 | 308.8 | 1.64 | 1.216 | 0.923
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
200 + 300 mg/kg per day
Mean | 5.49 | 7.94^**^ | 14.8 | 44.4 | 56.1^**^ | 18.8^**^ | 1,174 | 4.3 | 1.28 | 3.93
SD | 1.501 | 0.602 | 0.97 | 3.06 | 2.86 | 0.83 | 277.4 | 1.50 | 0.810 | 1.021
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 19 | 20 | 20
200 + 1,500 mg/kg per day
Mean | 5.25^*^ | 7.91^**^ | 15.0 | 46.1 | 58.5^**^ | 19.0^**^ | 1,262 | 4.3 | 1.16 | 3.74
SD | 1.374 | 0.814 | 1.20 | 3.42 | 3.81 | 1.05 | 268.9 | 2.04 | 0.566 | 1.126
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
200 + 3,000 mg/kg per day
Mean | 4.28^**^ | 7.88^**^ | 15.1 | 46.2 | 58.2^**^ | 19.2^**^ | 1,277 | 4.9 | 0.98^*^ | 3.02
SD | 1.118 | 1.329 | 2.71 | 8.53 | 4.21 | 0.92 | 421.7 | 2.35 | 0.704 | 0.610
n | 17 | 17 | 17 | 17 | 17 | 17 | 17 | 17 | 17 | 17
400 + 300 mg/kg per day
Mean | 5.61 | 7.98^**^ | 14.9 | 45.4 | 57.0^**^ | 18.8^**^ | 1,291 | 4.5 | 0.99^*^ | 4.32
SD | 1.398 | 0.872 | 1.46 | 4.08 | 2.48 | 0.66 | 327.6 | 1.64 | 0.409 | 1.193
n | 19 | 19 | 19 | 19 | 19 | 19 | 19 | 19 | 19 | 19
400 + 1,500 mg/kg per day
Mean | 4.97^**^ | 7.82^**^ | 14.9 | 45.5 | 58.2^**^ | 19.1^**^ | 1,295 | 4.7 | 0.88^**^ | 3.74
SD | 0.967 | 0.571 | 0.80 | 2.37 | 3.07 | 0.97 | 379.3 | 1.78 | 0.347 | 0.766
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20
400 + 3,000 mg/kg per day
Mean | 4.21^**^ | 5.69^**^ | 10.4^**^ | 31.7^**^ | 53.6^**^ | 17.8^**^ | 2,166^**^ | 4.6 | 0.71^**^ | 3.23
SD | 1.392 | 2.226 | 4.53 | 15.15 | 7.49 | 1.66 | 773.5 | 3.10 | 0.441 | 1.058
n | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20 | 20

a WBC=leukocytes, RBC=erythrocytes, HGB=hemoglobin, HCT=hematocrit, MCV=mean cell volume, MCH=mean cell hemoglobin, PLT=platelets, RETIC=reticulocytes, NEUT=neutrophils, LYMPH=lymphocytes

b AZT + pyrazinamide

* Significantly different (P<0.05) from the control by Dunnett’s test

** Significantly different (P<0.01) from the control by Dunnett’s test

Female-B Mice

| WBC | RBC | HGB | HCT | MCV | MCH | PLT | RETIC | NEUT | LYMPH
| 10^3^/L | 10^6^/L | g/dL | % | fL | pg | 10^3^/L | 10^5^/L | 10^3^/L | 10^3^/L
0 + 0 mg/kg per day^b^
Mean | 5.87 | 8.51 | 14.4 | 43.4 | 51.1 | 17.0 | 1,294 | 5.5 | 1.43 | 4.08
SD | 1.877 | 0.504 | 0.96 | 2.12 | 1.78 | 0.56 | 252.4 | 1.78 | 0.812 | 1.245
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
200 + 0 mg/kg per day^b^
Mean | 5.78 | 8.15 | 14.1 | 43.2 | 53.2 | 17.4 | 1,278 | 6.1 | 1.35 | 4.06
SD | 1.090 | 0.844 | 1.08 | 2.77 | 2.92 | 0.73 | 312.7 | 2.27 | 0.497 | 0.653
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
400 + 0 mg/kg per day^b^
Mean | 6.09 | 7.98 | 14.1 | 42.6 | 53.6^*^ | 17.7 | 1,277 | 5.2 | 1.11 | 4.53
SD | 1.674 | 0.924 | 1.59 | 3.84 | 2.55 | 0.66 | 279.6 | 1.14 | 0.364 | 1.497
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
0 + 300 mg/kg per day
Mean | 6.43 | 8.68 | 14.6 | 44.2 | 51.0 | 16.8 | 1,289 | 5.3 | 1.22 | 4.88
SD | 1.631 | 0.782 | 1.11 | 3.40 | 2.34 | 0.53 | 261.0 | 1.22 | 0.460 | 1.271
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
0 + 1,500 mg/kg per day
Mean | 5.78 | 9.02 | 15.4 | 46.0 | 51.1 | 17.1 | 1,371 | 4.7 | 1.11 | 4.37
SD | 1.762 | 1.043 | 1.48 | 3.97 | 2.48 | 0.64 | 347.6 | 1.23 | 0.417 | 1.601
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
0 + 3,000 mg/kg per day
Mean | 5.88 | 9.29 | 15.6 | 46.6 | 50.3 | 16.8 | 1,289 | 4.2 | 1.22 | 4.23
SD | 1.954 | 0.754 | 1.20 | 2.26 | 2.46 | 0.73 | 300.8 | 1.46 | 0.443 | 1.582
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
200 + 300 mg/kg per day
Mean | 6.44 | 8.56 | 14.9 | 45.1 | 52.8 | 17.4 | 1,345 | 6.1 | 1.28 | 4.77
SD | 2.317 | 0.912 | 1.45 | 4.07 | 2.08 | 0.65 | 342.6 | 1.55 | 0.375 | 1.904
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
200 + 1,500 mg/kg per day
Mean | 6.56 | 8.15 | 14.9 | 45.2 | 55.5^**^ | 18.3^**^ | 1,484 | 6.0 | 1.46 | 4.69
SD | 1.941 | 0.797 | 1.44 | 4.06 | 1.91 | 0.56 | 270.9 | 2.12 | 0.531 | 1.664
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
200 + 3,000 mg/kg per day
Mean | 6.21 | 8.36 | 15.1 | 45.5 | 54.6^**^ | 18.1^**^ | 1,376 | 4.8 | 1.46 | 4.33
SD | 1.401 | 0.766 | 1.09 | 3.25 | 2.91 | 0.88 | 252.9 | 1.87 | 0.934 | 1.136
n | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15 | 15
400 + 300 mg/kg per day
Mean | 6.61 | 8.14 | 14.3 | 44.0 | 54.3^**^ | 17.6 | 1,321 | 6.1 | 1.55 | 4.63
SD | 1.898 | 0.648 | 0.74 | 2.20 | 2.44 | 0.82 | 203.5 | 1.53 | 0.976 | 1.070
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
400 + 1,500 mg/kg per day
Mean | 6.31 | 8.61 | 15.4 | 46.1 | 53.8^*^ | 17.9^**^ | 125 | 5.4 | 1.57 | 4.38
SD | 2.690 | 1.263 | 1.70 | 5.02 | 2.74 | 0.89 | 274.8 | 1.52 | 1.358 | 1.646
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16
400 + 3,000 mg/kg per day
Mean | 6.59 | 8.89 | 15.4 | 47.2 | 53.2 | 17.4 | 1,392 | 5.4 | 1.55 | 4.60
SD | 2.319 | 0.880 | 1.17 | 3.36 | 2.54 | 0.83 | 288.6 | 1.99 | 1.418 | 1.908
n | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16 | 16

a WBC=leukocytes, RBC=erythrocytes, HGB=hemoglobin, HCT=hematocrit, MCV=mean cell volume, MCH=mean cell hemoglobin, PLT=platelets, RETIC=reticulocytes, NEUT=neutrophils, LYMPH=lymphocytes

b AZT + pyrazinamide

* Significantly different (P<0.05) from the control by Dunnett’s test

** Significantly different (P<0.01) from the control by Dunnett’s test

TABLE B2 Clinical Chemistry Data for Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Male Mice

| Alkaline Phosphatase | Alanine Aminotransferase | Aspartate Aminotransferase | Sorbitol Dehydrogenase | Total Bile Acids
| U/L | U/L | U/L | U/L | μmol/L
0 + 0 mg/kg per day^a^
Mean | 56 | 29 | 60 | 25 | 9
SD | 15.9 | 13.7 | 20.8 | 6.6 | 3.1
n | 10 | 8 | 3 | 6 | 3
200 + 0 mg/kg per day
Mean | 56 | 27 | 89 | 19 | 22
SD | 3.3 | 12.2 | 58.8 | 3.9 | 12.4
n | 10 | 10 | 6 | 4 | 6
400 + 0 mg/kg per day
Mean | 58 | 27 | 56 | 25 | 7
SD | 14.9 | 9.3 | 26.4 | 4.2 | 7.8
n | 10 | 10 | 5 | 3 | 2
0 + 300 mg/kg per day
Mean | 61 | 26 | 51 | 10 | 5
SD | 19.1 | 10.2 | 21.0 | 9.0 | 4.2
n | 10 | 8 | 6 | 3 | 2
0 + 1,500 mg/kg per day
Mean | 55 | 42 | 66 | 26 | 24
SD | 14.8 | 13.4 | 26.6 | 8.4 | 19.1
n | 10 | 10 | 4 | 3 | 3
0 + 3,000 mg/kg per day
Mean | 49 | 27 | 40 | 24 | 16
SD | 9.6 | 10.0 | 3.8 | 10.0 | 11.2
n | 9 | 9 | 3 | 6 | 3
200 + 300 mg/kg per day
Mean | 55 | 34 | 63 | 26 | 24
SD | 18.9 | 13.8 | 15.1 | 4.7 | 20.5
n | 10 | 10 | 4 | 4 | 2
200 + 1,500 mg/kg per day
Mean | 55 | 30 | 68 | 34 | 21
SD | 19.3 | 10.9 | 16.9 | 19.7 | 6.5
n | 10 | 10 | 7 | 6 | 4
200 + 3,000 mg/kg per day
Mean | 59 | 40 | 58 | 37 | 23
SD | 27.8 | 32.0 | 11.4 | 4.1 | 9.9
n | 8 | 8 | 6 | 5 | 6
400 + 300 mg/kg per day
Mean | 57 | 28 | 60 | 19 | 20
SD | 14.0 | 12.4 | 23.6 | 8.0 | 9.5
n | 10 | 9 | 7 | 3 | 6
400 + 1,500 mg/kg per day
Mean | 55 | 32 | 46 | 34 | 23
SD | 17.4 | 15.5 | 27.0 | 14.5 | 4.9
n | 10 | 10 | 5 | 5 | 2
400 + 3,000 mg/kg per day
Mean | 49 | 65 | 54 | 38 | 25
SD | 20.2 | 93.2 | 19.2 | 11.1 | 9.1
n | 8 | 8 | 7 | 4 | 6

a AZT + pyrazinamide

Female-A Mice

| Alkaline Phosphatase | Alanine Aminotransferase | Aspartate Aminotransferase | Sorbitol Dehydrogenase | Total Bile Acids
| U/L | U/L | U/L | U/L | μmol/L
0 + 0 mg/kg per day^a^
Mean | 68 | 36 | 84 | 19 | 26
SD | 21.5 | 15.5 | 40.5 | 6.6 | 20.4
n | 20 | 20 | 16 | 18 | 15
200 + 0 mg/kg per day
Mean | 69 | 31 | 87 | 21 | 19
SD | 15.8 | 11.2 | 31.3 | 8.9 | 8.1
n | 20 | 19 | 17 | 17 | 14
400 + 0 mg/kg per day
Mean | 82 | 28 | 93 | 21 | 22
SD | 17.8 | 10.4 | 36.3 | 7.4 | 12.1
n | 20 | 20 | 12 | 19 | 12
0 + 300 mg/kg per day
Mean | 55 | 34 | 80 | 20 | 18
SD | 16.7 | 9.3 | 21.2 | 9.6 | 6.9
n | 20 | 20 | 14 | 17 | 10
0 + 1,500 mg/kg per day
Mean | 63 | 36 | 83 | 27 | 22
SD | 17.6 | 10.0 | 20.5 | 8.9 | 11.1
n | 20 | 19 | 14 | 16 | 10
0 + 3,000 mg/kg per day
Mean | 64 | 36 | 88 | 26 | 43
SD | 16.7 | 13.3 | 26.7 | 11.6 | 26.1
n | 20 | 20 | 13 | 16 | 7
200 + 300 mg/kg per day
Mean | 63 | 32 | 88 | 26 | 18
SD | 17.1 | 9.1 | 27.3 | 10.3 | 7.8
n | 20 | 19 | 16 | 15 | 12
200 + 1,500 mg/kg per day
Mean | 70 | 41 | 73 | 28 | 33
SD | 19.4 | 26.6 | 30.2 | 8.8 | 22.0
n | 20 | 20 | 16 | 19 | 13
200 + 3,000 mg/kg per day
Mean | 80 | 26 | 65 | 26 | 16
SD | 55.5 | 9.5 | 29.2 | 6.9 | 6.1
n | 17 | 14 | 10 | 11 | 6
400 + 300 mg/kg per day
Mean | 72 | 31 | 88 | 25 | 20
SD | 13.2 | 10.7 | 24.6 | 6.0 | 9.5
n | 19 | 19 | 15 | 14 | 9
400 + 1,500 mg/kg per day
Mean | 69 | 33 | 70 | 29 | 24
SD | 14.7 | 11.8 | 20.1 | 8.4 | 8.0
n | 20 | 20 | 15 | 15 | 10
400 + 3,000 mg/kg per day
Mean | 71 | 28 | 64 | 33 | 26
SD | 51.9 | 9.2 | 21.9 | 8.8 | 13.1
n | 20 | 19 | 16 | 18 | 15

a AZT + pyrazinamide

## Other NIEHS Reports and Publications on Toxicology of AIDS Therapeutics:

National Institute of Environmental Health Sciences (NIEHS) (1997). Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 1. NIH Publication No. 97-3938. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1998). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT), Trimethoprim (TMP)/Sulfamethoxazole (SMX), and Folinic Acid Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 2. NIH Publication No. 99-3940. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (1999). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Isoniazid Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 3. NIH Publication No. 99-3941. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Reproductive, Developmental, and General Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Rifabutin Combinations Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 4. NIH Publication No. 00-3948. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2000). Subchronic Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Pyrazinamide Combinations Administered by Gavage to B6C3F1 Mice. NIEHS AIDS Therapeutics Toxicity Report No. 5. NIH Publication No. 00-3949. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Institute of Environmental Health Sciences (NIEHS) (2001). Subchronic Toxicity Studies of 3′-Azido-3′-deoxythymidine (AZT)/Rifampicin Combinations Administered by Gavage to B6C3F1 Mice. NIEHS AIDS Therapeutics Toxicity Report No. 6. NIH Publication No. 01-4401. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
Rao, G.N., Collins, B.J., Giles, H.D., Heath, J.E., Foley, J.F., May, R.D., and Buckley, L.A. (1996). Carcinogenicity of 2′,3′-dideoxycytidine in mice. Cancer Res. 56, 4666–4672.8840982
Rao, G.N., Lindamood, C., Heath, J.E., Farnell, D.R., and Giles, H.D. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F1 mice. Toxicol. Sci. 45, 113–127.9848118
Sanders, V.M., Elwell, M.R., Heath, J.E., Collins, B.J., Dunnick, J.K., Rao, G.N., Prejean, D., Lindamood, C., and Irwin, R.D. (1995). Induction of thymic lymphoma in mice administered the dideoxynucleosideddC. Fundam. Appl. Toxicol. 27, 263–269.8529822
Zhuang, S.-M., Eklund, L.K., Cochran, C., Rao, G.N., Wiseman, R.W., and Soderkvist, P. (1996). Allelotype analysis of 2′,3′-dideoxycytidine- and 1,3-butadiene-induced lymphomas in B6C3F1 Mice. Cancer Res. 56, 3338–3343.8764131