# APPENDIX A Body Weights and Organ Weights

TABLE A1 Group Mean Body Weights of Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Male Mice

Dose^a^ | Mean Body Weights^b^ on Study Day
Dose^a^ | 3 | 5 | 9 | 13 | 17 | 21 | 23
0 + 0 | 37.9 ± 1.8 | 38.2 ± 1.5 | 37.6 ± 1.4 | 37.0 ± 1.6 | 37.8 ± 2.0 | 37.1 ± 1.8 | 38.0 ± 1.9
200 + 0 | 38.1 ± 1.3 | 38.2 ± 1.7 | 37.6 ± 1.7 | 37.1 ± 1.7 | 37.9 ± 1.8 | 37.8 ± 1.8 | 37.9 ± 1.9
400 + 0 | 37.3 ± 1.9 | 37.3 ± 1.6 | 37.4 ± 1.3 | 36.7 ± 1.2 | 37.4 ± 1.6 | 37.3 ± 1.2 | 37.9 ± 1.8
0 + 300 | 37.2 ± 1.7 | 36.4 ± 3.6 | 37.6 ± 1.8 | 37.2 ± 2.1 | 37.6 ± 2.2 | 37.4 ± 2.4 | 37.8 ± 2.5
0 + 1,500 | 37.7 ± 2.2 | 38.9 ± 2.6 | 38.6 ± 2.1 | 38.3 ± 2.3 | 38.8 ± 2.2 | 39.0 ± 2.3 | 39.6 ± 2.2
0 + 3,000 | 37.1 ± 2.3 | 37.7 ± 2.4 | 36.9 ± 2.2 (9) | 37.6 ± 2.6 (9) | 38.9 ± 2.5 (9) | 39.7 ± 2.8 (9) | 39.7 ± 2.8 (9)
200 + 300 | 37.6 ± 2.2 | 37.4 ± 2.4 | 37.7 ± 2.0 | 37.3 ± 1.7 | 37.7 ± 1.7 | 37.6 ± 1.5 | 37.9 ± 1.5
200 + 1,500 | 37.1 ± 1.5 | 37.1 ± 1.8 | 37.7 ± 1.6 | 36.9 ± 2.1 | 37.5 ± 2.2 | 37.8 ± 2.3 | 38.8 ± 2.2
200 + 3,000 | 37.4 ± 1.8 | 37.7 ± 2.9 | 37.2 ± 2.2 (8) | 37.4 ± 1.3 (8) | 38.1 ± 1.6 (8) | 38.8 ± 1.6 (8) | 38.6 ± 1.6 (8)
400 + 300 | 37.4 ± 1.8 | 36.5 ± 2.6 | 37.5 ± 1.8 | 36.8 ± 1.4 | 38.2 ± 1.5 | 36.9 ± 3.2 | 38.0 ± 1.8
400 + 1,500 | 36.6 ± 2.3 | 37.5 ± 1.9 | 38.6 ± 2.0 | 37.7 ± 2.4 | 38.8 ± 2.8 | 38.5 ± 2.4 | 38.4 ± 2.4
400 + 3,000 | 38.2 ± 1.8 | 38.8 ± 2.0 | 39.2 ± 1.8 (8) | 39.1 ± 1.7 (8) | 40.5 ± 2.3 (8) | 39.9 ± 2.0 (8) | 40.2 ± 2.6 (8)

a Doses expressed as AZT + pyrazinamide in mg/kg per day

b Weights (grams) expressed as group mean ± standard deviation; n=10 unless otherwise noted in parentheses

Female-A Mice

Dose^a^ | Mean Body Weights^b^ on Study Day
Dose^a^ | 3 | 5 | 9 | 13 | 17 | 21 | 23
0 + 0 | 28.3 ± 1.4 | 28.9 ± 1.4 | 29.3 ± 1.5 | 31.4 ± 2.2 | 33.2 ± 2.8 | 37.2 ± 4.9 | 43.2 ± 8.2
200 + 0 | 29.6 ± 2.0 | 30.4 ± 1.7 | 29.9 ± 2.0 | 31.6 ± 2.1 | 33.6 ± 3.0 | 37.8 ± 4.3 | 43.6 ± 6.3 (19)
400 + 0 | 29.4 ± 1.7 | 29.6 ± 1.7 | 29.6 ± 2.5 | 30.4 ± 1.7 | 32.4 ± 1.7 | 34.8 ± 2.6 | 36.7 ± 4.7
0 + 300 | 29.3 ± 2.1 | 29.5 ± 2.1 | 29.8 ± 1.7 | 31.2 ± 2.0 | 33.2 ± 2.3 | 37.4 ± 4.3 | 43.5 ± 7.0
0 + 1,500 | 29.3 ± 2.0 | 29.6 ± 1.8 | 30.1 ± 1.4 | 32.2 ± 1.7 | 34.8 ± 2.4 | 38.8 ± 3.9 | 44.6 ± 6.3
0 + 3,000 | 29.4 ± 2.0 | 29.8 ± 1.6 | 30.3 ± 1.8 | 33.0 ± 2.0 | 35.4 ± 3.1 | 39.6 ± 4.1 (19) | 44.6 ± 6.0
200 + 300 | 29.4 ± 1.7 | 29.4 ± 1.6 | 29.6 ± 1.7 | 31.2 ± 1.8 | 32.8 ± 2.3 | 35.5 ± 4.1 | 39.0 ± 6.8
200 + 1,500 | 29.8 ± 1.2 | 30.3 ± 1.1 | 30.4 ± 1.5 | 32.8 ± 1.6 | 34.8 ± 2.5 | 37.2 ± 4.8 | 39.9 ± 7.4
200 + 3,000 | 30.2 ± 1.6 | 31.0 ± 1.5 | 30.7 ± 1.7 (18) | 32.6 ± 1.6 (18) | 34.4 ± 2.0 (17) | 34.6 ± 3.1 (17) | 34.4 ± 2.5^*^++ (17)
400 + 300 | 29.2 ± 1.4 | 29.7 ± 1.4 | 29.5 ± 1.4 | 30.4 ± 2.3 | 32.6 ± 2.3 (19) | 35.7 ± 3.5 (19) | 38.3 ± 6.4 (18)
400 + 1,500 | 29.7 ± 1.3 | 30.4 ± 1.2 | 30.4 ± 1.3 | 31.7 ± 1.5 | 32.8 ± 1.9 | 33.4 ± 2.6 | 33.6 ± 4.1^**^
400 + 3,000 | 30.4 ± 2.2 | 31.6 ± 2.2 | 31.8 ± 2.1^*^ | 33.4 ± 1.7− | 34.0 ± 2.3 | 34.2 ± 2.7 | 33.8 ± 3.5^*^

a Doses expressed as AZT + pyrazinamide in mg/kg per day

b Weights (grams) expressed as group mean ± standard deviation; n=20 unless otherwise noted in parentheses

* P ≤ 0.05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P ≤ 0.01 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

++ P ≤ 0.01 compared to 200 + 0 group by Scheffe’s or Dunn’s test

− P ≤ 0.01 compared to 400 + 0 group by Scheffe’s or Dunn’s test

Female-B Mice

Dose^a^ | n | Mean Body Weights^b^ on Study Day
Dose^a^ | n | Day of Gestation | | | | Day of Lactation
Dose^a^ | n | 0 | 8 | 12 | 15 | 0 | 1 | 4
0 + 0 | 15 | 29.7 ± 1.3 | 34.4 ± 2.0 | 41.8 ± 4.0 | 49.8 ± 3.1 | 37.1 ± 2.1 | 38.0 ± 2.3 | 44.8 ± 3.0
200 + 0 | 14 | 29.4 ± 1.2 | 34.6 ± 1.7 | 40.8 ± 2.5 | 48.8 ± 3.2 | 36.3 ± 2.3 | 37.4 ± 1.8 | 44.0 ± 2.3
400 + 0 | 14 | 29.3 ± 1.1 | 34.3 ± 2.3 | 40.4 ± 3.5 | 46.6 ± 4.2 | 36.7 ± 2.5 | 36.2 ± 2.9 | 41.75.2
0 + 300 | 14 | 29.3 ± 1.6 | 34.1 ± 1.6 | 40.8 ± 2.6 | 48.3 ± 3.5 | 36.5 ± 2.1 (13) | 37.3 ± 3.1 (13) | 44.3 ± 3.2 (13)
0 + 1,500 | 14 | 29.7 ± 1.6 | 35.2 ± 2.2 | 41.4 ± 2.8 | 47.7 ± 4.0 | 36.0 ± 3.4 (13) | 37.9 ± 3.0 (13) | 44.0 ± 2.8 (13)
0 + 3,000 | 14 | 29.3 ± 1.4 | 35.1 ± 2.0 | 39.8 ± 3.2 | 46.0 ± 4.0 | 36.4 ± 2.7 (11) | 37.4 ± 2.9 (11) | 43.0 ± 4.1 (11)
200 + 300 | 12 | 29.2 ± 1.8 | 33.9 ± 2.0 | 38.6 ± 3.6 | 46.3 ± 3.8 | 35.6 ± 2.1 (11) | 37.0 ± 2.2 (11) | 42.4 ± 4.2 (11)
200 + 1,500 | 16 | 29.2 ± 1.3 | 34.2 ± 1.7 | 39.8 ± 2.2 | 46.1 ± 2.4 | 36.4 ± 1.6 | 36.5 ± 2.0 | 40.8 ± 4.1
200 + 3,000 | 15 | 29.7 ± 1.2 | 35.4 ± 2.3 | 40.7 ± 2.9 | 47.3 ± 2.5 (14) | 37.0 ± 1.9 (12) | 36.6 ± 1.4 (12) | 41.6 ± 3.5 (12)
400 + 300 | 13 | 29.4 ± 1.3 | 34.1 ± 1.4 | 39.4 ± 1.7 | 46.5 ± 2.4 | 36.4 ± 2.0 | 36.5 ± 2.1 | 42.8 ± 2.9
400 + 1,500 | 13 | 29.8 ± 1.4 | 35.2 ± 2.8 | 40.8 ± 3.3 | 46.9 ± 3.9 | 37.1 ± 2.6 | 36.6 ± 2.6 | 40.4 ± 5.7
400 + 3,000 | 15 | 29.5 ± 1.2 | 34.9 ± 1.7 | 40.4 ± 2.2 | 43.7 ± 3.2^*^ | 37.7 ± 0.6 (3) | 36.5 ± 0.7 (3) | 39.0 ± 0.0 (3)

a Doses expressed as AZT + pyrazinamide in mg/kg per day

b Weights (grams) expressed as group mean ± standard deviation; n=20 unless otherwise noted in parentheses

* P ≤ 0.05 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

** P ≤ 0.01 compared to 0 + 0 (control) group by Scheffe’s or Dunn’s test

++ P ≤ 0.01 compared to 200 + 0 group by Scheffe’s or Dunn’s test

− P ≤ 0.01 compared to 400 + 0 group by Scheffe’s or Dunn’s test

TABLE A2 Group Mean Organ Weights of Mice in the Reproductive, Developmental, and General Toxicity Study of AZT and Pyrazinamide Combinations

Male Mice

Dose^a^ | Body | Right Epididymis Weight^b^ | | Liver Weight^b^
Dose^a^ | Weight^b^ | Absolute | Relative | Absolute | Relative
0 + 0 | 38.15 | 0.04552 ± 0.0645 | 1.2 ± 0.2 | 2.0830 ± 0.2734 | 54.6 ± 7.1
200 + 0 | 39.79 | 0.04534 ± 0.00529 ( − 0.4) | 1.1 ± 0.1 ( − 4.6) | 2.1510 ± 0.2615 ( + 3.3) | 54.0 ± 4.0 ( − 1.1)
400 + 0 | 38.60 | 0.04495 ± 0.00599 ( − 1.3) | 1.2 ± 0.2 ( − 2.1) | 2.0080 ± 0.2917 ( − 3.6) | 51.9 ± 6.0 ( − 4.9)
0 + 300 | 38.50 | 0.04147 ± 0.00450 ( − 8.9) | 1.1 ± 0.2 ( − 9.3) | 2.2120 ± 0.3978 ( + 6.2)^c^ | 57.2 ± 6.8 ( + 4.7)
0 + 1,500 | 40.33^*^ | 0.04794 ± 0.00512 ( + 5.3) | 1.2 ± 0.1 ( − 0.6) | 2.3780 ± 0.3048 ( + 14.2)^*^ | 58.8 ± 5.0 ( + 7.7)
0 + 3,000^c^ | 40.19^*^ | 0.04183 ± 0.00352 ( − 8.1) | 1.0 ± 0.1 ( − 12.4)^*^ | 2.3567 ± 0.1667 ( + 13.1)^*^ | 58.7 ± 3.6 ( + 7.6)
200 + 300 | 39.40 | 0.04770 ± 0.00585 ( + 4.8) | 1.2 ± 0.2 ( + 1.8) | 2.1630 ± 0.2001 ( + 3.8) | 54.8 ± 3.2 ( + 0.5)
200 + 1,500 | 39.54 | 0.04833 ± 0.00518 ( + 6.2) | 1.2 ± 0.1 ( + 2.6) | 2.3570 ± 0.3599 ( + 13.2)^*^ | 59.4 ± 6.6 ( + 8.9)^*^
200 + 3,000^d^ | 39.66 | 0.04574 ± 0.00546 ( + 0.5) | 1.2 ± 0.1 ( − 3.7) | 2.5200 ± 0.2700 ( + 21.0)^*^ | 63.4 ± 4.9 ( + 16.2)^*^
400 + 300 | 38.79 | 0.04359 ± 0.00587 ( − 4.2) | 1.1 ± 0.2 ( − 5.8) | 2.1780 ± 0.2288 ( + 4.6) | 56.1 ± 4.9 ( + 2.8)
400 + 1,500 | 39.15 | 0.04903 ± 0.00706 ( + 7.7) | 1.3 ± 0.2 ( + 4.8) | 2.3300 ± 0.2053 ( + 11.9)^*^ | 59.5 ± 3.7 ( + 9.0)^*^
400 + 3,000^d^ | 41.06^*^ | 0.04548 ± 0.00718 ( − 0.1) | 1.1 ± 0.2 ( − 7.0) | 2.5500 ± 0.2240 ( + 22.4)^*^ | 62.2 ± 4.9 ( + 13.8)^*^

a Doses expressed as AZT + pyrazinamide in mg/kg per day

b Values are presented as mean ± standard deviation (% difference from control); n=10 unless otherwise noted. Organ weights and body weights are given in grams; relative organ weights (organ-weight-to-body-weight ratios) are given as mg organ weight/g body weight.

c n=9

d n=8

* P ≤ 0.05 compared to the 0 + 0 (control) group by the Student’s t-test

Female-A Mice

Dose^a^ | n | Corrected | Liver Weight^c^
Dose^a^ | n | Body Weight^b^ | Absolute | Relative
0 + 0 | 13 | 37.40 | 2.7069 ± 0.2643 | 72.5 ± 5.9
200 + 0 | 15 | 36.28 | 2.4387 ± 0.3601 ( − 9.9) | 66.9 ± 5.3 ( − 7.6)^*^
400 + 0 | 16 | 36.01 | 2.2581 ± 0.3822 ( − 16.6)^*^ | 62.4 ± 6.2 ( − 13.9)^*^
0 + 300 | 15 | 37.33 | 2.7733 ± 0.3219 ( + 2.5) | 74.5 ± 6.9 ( + 2.7)
0 + 1,500 | 12 | 37.96 | 2.9517 ± 0.3150 ( + 9.0) | 77.6 ± 5.4 ( + 7.1)
0 + 3,000 | 13 | 39.29 | 3.2400 ± 0.3844 ( + 19.7)^*^ | 82.4 ± 7.4 ( + 13.8)^*^
200 + 300 | 14 | 37.04 | 2.6436 ± 0.4133 ( − 2.3) | 71.0 ± 7.1 ( − 2.0)
200 + 1,500 | 12 | 38.08 | 2.9908 ± 0.5169 ( + 10.5) | 78.1 ± 9.4 ( + 7.7)^*^
200 + 3,000 | 5 | 35.83 | 2.4900 ± 0.3195 ( − 8.0) | 69.4 ± 6.2 ( − 4.3)
400 + 300 | 15 | 35.88 | 2.4140 ± 0.5276 ( − 10.8) | 66.6 ± 9.1 ( − 8.2)
400 + 1,500 | 6 | 36.80 | 2.6733 ± 0.4301 ( − 1.2) | 72.4 ± 8.4 ( − 0.1)
400 + 3,000 | 4 | 36.02 | 2.8525 ± 0.3024 ( + 5.4) | 79.1 ± 2.3 ( + 9.1)

a Doses expressed as AZT + pyrazinamide in mg/kg per day

b Total body weight minus gravid uterine weight in grams

c Values are presented as mean ± standard deviation (% difference from control). Organ weights and body weights are given in grams; relative organ weights (organ-weight-to-body-weight ratios) are given as mg organ weight/g body weight.

n Number of values included in calculations. Values exclude early deaths, dams designated as not pregnant, dams that delivered or began delivery prior to scheduled sacrifice, and dams that were sacrificed on an estimated day 14 or 18 of gestation.

* P≤0.05 compared to the 0 + 0 (control) group by the Student’s t-test