# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine: An overview. Am. J. Med. 85, 186–188.3044084
Barnes, P.F., Bloch, A.B., Davidson, P.T., and Snider, D.E., Jr. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Engl. J. Med 324, 1644–1650.2030721
Bichel, J. (1973). Rifampicin in a carcinogenic experiment. Lancet 2, 1209.
Binda, G., Domenichini, E., Gottardi, A., Orlandi, B., Ortelli, E., Pacini, B., and Fowst, G. (1971). Rifampicin, a general review. Arzeneimittelforschung 21, 1907–1977.
Centers for Disease Control (CDC) (1987). Diagnosis and management of mycobacterial infection and disease in persons with human immunodeficiency virus infection. Ann. Intern. Med 106, 254–256.3800186
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Curci, C. (1969). Some aspects of the pharmacokinetics of rifampicin. Acta Tuberc. Pneumol. Belg. 60, 276–287.5371665
Della Porta, G., Cabral, J.R., and Rossi, L. (1978). Carcinogenicity study of rifampicin in mice and rats. Toxicol. Appl. Pharmacol. 43, 293–302.635918
Dixon, W.J., and Massey, F.J., Jr. (1951). Introduction to Statistical Analysis, 1st ed., pp.145–147. McGraw-Hill Book Company, Inc., New York.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1095–1121.
Editorial Staff (1971). Rifampicin: A review. Drugs 1, 354–398.4949280
Freirich, E.J., Gehon, E.A., Rall, D.P., Schmidt, L.H., and Skipper, H.E. (1966). Quantitative comparison of toxicity of anticancer agents in mouse, rat, hamster, dog, monkey, and man. Cancer Chemother. Rep. 50, 219–244.4957125
Furesz, S. (1970). Chemical and biological properties of rifampicin. Antibiot. Chemother. 16, 316–351.5002304
Girling, D.J., and Hitze, K.L. (1979). Adverse reactions to rifampicin. Bull. World Health Organ. 57(1), 45–49.311712
Goldschmidt, R.H., and Dong, B.J. (1992). Current report-HIV treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. N. Engl. J. Med 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Gronhagen-Riska, C., Hellstrom, P.E., and Forseth, B. (1978). Predisposing factors in hepatitis induced by isoniazid-rifampin treatment of tuberculosis. Am. Rev. Respir. Dis. 188, 461–466.
Grosset, J., and Levintis, S. (1983). Adverse effects of rifampin. Rev. Infect. Dis. 5 (Suppl. 3), S440–S446.6356277
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (Ois). AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Hugues, F.-C., Marche, C., and Marche, J. (1969). Effets hépato-biliaires de l’association rifampicine-isoniazide. Thérapie 24, 899.5364210
International Agency for Research on Cancer (IARC) (1986). IARC Monographs on the Evaluation of the Carcinogenic Risk of Chemicals to Humans, Vol. 24. IARC, Lyon, France.
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Infect. 18 (Suppl. 1), 5–13.2464649
Jonckheere, A.R. (1954). Adistribution-freek-sample test against ordered alternatives. Biometrika. 41, 133–145.
Mansuri, M.M., Hitchcock, M.J., Buroker, R.A., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biological properties and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Vande Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. N. Engl. J. Med. 305, 1431–1438.6975437
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/αInterferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. Research Triangle Park, N.C.
Nolan, C.M. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Am. J. Infect. Control 20, 30–34.1554145
Physicians’ Desk Reference (PDR) (1996). 50th ed., pp. 1158–1163. Medical Economics Data, Medical Economics Company, Inc., Montvale, NJ.
Piriou, A., Wamet, J.M., Jacqueson, A., Clause, J.R., and Truhaut, R. (1979). Fatty liver induced by high doses of rifampicin in the rat: possible relation with an inhibition of RNA polymerases in eukariotic cells. Arch. Toxicol Suppl. 2, 333–337.
Radner, D.B. (1973). Toxicologic and pharmacologic aspects of rifampin. Chest 64, 213–216.4199024
Rao, G. N., Lindamood, C., III., Heath, J. E., Farnell, D. R., and Giles, H. D. (1998). Subchronic toxicity of human immunodeficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infect. Dis. Clin. North Am. 2, 397–497.2462584
Scheuer, P.J., Summerfield, J.A., Lai, S., and Sherlock, S. (1974). Rifampin hepatitis. Lancet 1, 421–425.4131429
Siegle, F.P., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. N. Engl. J. Med. 305, 1439–1444.6272110
Stevens, J. (1986). Applied Multivariate Statistics for the Social Sciences. Chapter 3. LEA Publishers.
Thompson, M.B., Dunnick, J.K., Sutphin, M.E., Giles, H.D., Irwin, R.D., and Prejean, J.D. (1991). Hematologic toxicity of AZT and ddC administered as single agents and in combination to rats and mice. Fundam. Appl. Toxicol. 17, 159–176.1655546
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F1 mice. Drug Metab. Dispos. 21, 189–193.8095218
Vince, R., Hua, M., Brownell, J., Daluge, S., Lee, F.C., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, P.G., Schultz, R.H., Narayanan, V.L., Mayo, J.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against human immunodeficiency virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Warkany, J. (1979). Antituberculosis drugs. Teratology 20, 133–138.92814
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics 28, 519–531.5037867