# Peer Review

The draft report on the subchronic toxicity study of 3′-azido-3′-deoxythymidine (AZT) and rifampicin combinations was evaluated by the following reviewers. These reviewers served as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of these studies are appropriate and ensure that this subcbronic toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- Thomas L. Goldsworthy, DVM, Ph.D.
  Integrated Laboratory Systems, Inc.
  Research Triangle Park, NC
- Harold Davis, DVM, Ph.D.
  Amgen, Inc.
  Thousand Oaks, CA