# Results and Discussion

## Survival and Clinical Findings

Administration of AZT alone or rifampicin alone did not result in mortality. A total of 79 core study animals (34 males and 45 females) died from combination treatment with AZT and rifampicin. In general, mortality was increased and occurred earlier in females compared to males.

Seven male mice in the 400 mg AZT + 200 mg rifampicin group died during weeks 8 and 9; eight males that received 100 mg AZT + 400 mg rifampicin died during weeks 8 through 12. Nine and ten male mice, respectively, in the combination groups that received 200 or 400 mg AZT + 400 mg rifampicin died during weeks 7 and 8. Clinical findings were noted primarily in dose groups in which mortality occurred. These signs of toxicity included thinness, tremors, abnormal breathing, ataxia, lethargy, and ruffled fur and were noted in males in the 100 + 400, 200 + 400, 400 + 200, and 400 + 400 (AZT + rifampicin) groups beginning on day 50 of the study.

In general, female mice died earlier than males. One female that received 400 mg AZT + 100 mg rifampicin and three females that received 200 mg AZT + 200 mg rifampicin died during week 8. An additional female in the 200 mg AZT + 200 mg rifampicin group died during week 11. All females in the following dose groups died by week 7: 400 + 200, 100 + 400, 200 + 400, and 400 + 400 (AZT + rifampicin). Clinical: findings related to treatment were similar to those noted in males (thinness, tremors, abnormal breathing, ataxia, lethargy, ruffled fur) and were observed beginning on day 45 of the study.

## Body and Organ Weights

Administration of 100, 200, or 400 mg of AZT alone did not result in consistent treatment-related decreases in body weights of male or female mice (Table 3 and Figures 1 and 2). Respective final mean body weights of male mice treated with 200 or 400 mg of AZT alone were approximately 8% (34.66 grams; P≤0.05) and 4% (36.05 grams) lower than the mean (37.71 grams) of the male control group. Respective final mean body weights of female mice treated with 100, 200, or 400 mg of AZT alone were approximately 7% (26.95 grams), 2% (28.39 grams), and 4% (27.73 grams) lower than the mean (28.89 grams) of the female control group.

TABLE 3 Final Mean Body Weights, Organ Weights, and Organ-Weight-to-Body Weight Ratios of Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | n^b^ | Mean Body Weight (g) | Organ Weight^c^ (g) | Organ to Body Ratio × 1,000^c^ | Organ Weight (g) | Organ to Body Ratio × 1,000
Male
| | | Heart | | Right Kidney
0 + 0 | 10 | 37 71 | 0 151 ± 0120 | 4 0 ± 0 3 | 0 290 ± 0 025 | 7 7 ± 0 7
100 + 0 | 10 | 38 32 | 0 150 ± 0 007(−0 7) | 4 0 ± 0 4(−1 9) | 0 294 ± 0 018(+1 4) | 7 8 ± 0 8(+0 1)
200 + 0 | 10 | 34 66^**^ | 0 145 ± 0 010(−4 0) | 4 2 ± 0 3(+4 1) | 0 285 ± 0 020(−1 7) | 8 3 ± 0 8(+6 7)
400 + 0 | 10 | 36 05 | 0 149 ± 0 012(−1 3) | 4 2 ± 0 4(+3 1) | 0 280 ± 0 025(−3 4) | 7 8 ± 0 7(+0 6)
0+100 | 10 | 35 00^**^ | 0 146 ± 0 010(−3 3) | 4 2 ± 0 2(+3 6) | 0 294 ± 0 023(+1 4) | 8 4 ± 0 5(+8 5)^*^
100+100 | 10 | 35 88 | 0 152 ± 0 009(+0 7) | 4 2 ± 0 2(+5 1) | 0 289 ± 0 009(−0 3) | 8 1 ± 0 4(+4 1)
200 + 100 | 10 | 36 32 | 0 148 ± 0 009(−2 0) | 4 1 ± 0 3(+1 3) | 0 294 ± 0 025(+1 4) | 8 1 ± 0 7(+4 6)
400+ 100 | 10 | 35 53 | 0 150 ± 0 015(−0 7) | 4 2 ± 0 4(+5 0) | 0 297 ± 0 026(+2 4) | 8 4 ± 0 8(+8 4)^*^
0 + 200 | 10 | 35 71 | 0 140 ± 0 013(−7 3) | 3 9 ± 0 2(−2 7) | 0 296 ± 0 028(+2 1) | 8 3 ± 0 5(+7 0)
100 + 200 | 9 | 34 12^*^ | 0 144 ± 0 010(−4 3) | 4 2 ± 0 2(+5 2) | 0 284 ± 0 022(−1 9) | 8 3 ± 0 5(+7 7)^*^
200 + 200 | 10 | 32 69^**^ | 0 147 ± 0 008(−2 6) | 4 5 ± 0 2(+11 6)^**^ | 0 271 ± 0 022(−6 6) | 8 3 ± 0 3(+6 9)
400 + 200 | 3 | 34 87 | 0 183 ± 0 015(+21 4)^**^ | 5 3 ± 0 4(+30 3)^**^ | 0 293 ± 0 012(+1 1) | 8 4 ± 0 2(+8 6)
0 + 400 | 10 | 32 50^**^ | 0 132 ± 0 004(−12 6)^**^ | 4 1 ± 0 2(+0 9) | 0 262 ± 0 017(−9 7)^**^ | 8 1 ± 0 6(+4 2)
100 + 400 | 2 | 30 25^**^ | 0 155 ± 0 007(+2 6) | 5 1 ± 0 3(+27 4)^**^ | 0 235 ± 0 021(−19 0)^**^ | 7 8 ± 0 0(+0 3)
200 + 400 | 1 | 22 70^**^ | 0210(+39 1)^**^ | 9 3(+129 4)^**^ | 0230(−20 7)^*^ | 10 1(+30 8)^**^
| | | Liver | | Lung
0 + 0 | 10 | 37 71 | 1 677 ± 0 295 | 43 3 ± 3 1 | 0 228 ± 0 050 | 6 1 ± 1 2
100 + 0 | 10 | 38 32 | 1 676 ± 0 354(−0 1) | 43 5 ± 3 9(−1 9) | 0 223 ± 0 045(−2 2) | 5 9 ± 1 1(−3 8)
200 + 0 | 10 | 34 66^**^ | 1 505 ± 0 010(−10 3) | 43 5 ± 3 0(−1 8) | 0 222 ± 0 039(−2 6) | 6 4 ± 1 2(+5 9)
400 + 0 | 10 | 36 05 | 1 600 ± 0 134(−4 6) | 44 5 ± 2 4(+0 3) | 0 216 ± 0 035(−5 3) | 6 0 ± 0 9(−1 1)
0 + 100 | 10 | 35 00^**^ | 2 568 ± 0 197(+53 1)^**^ | 73 3 ± 2 4(+65 4)^**^ | 0 229 ± 0 056(+0 4) | 6 5 ± 1 5(+7 4)
100 + 100 | 10 | 35 88 | 2 661 ± 0 219(+58 7)^**^ | 74 1 ± 4 3(+67 2)^**^ | 0 212 ± 0 046(−7 0) | 5 9 ± 1 3(−2 9)
200 + 100 | 10 | 36 32 | 2 709 ± 0219(+61 5)^**^ | 74 5 ± 3 3(+68 1)^**^ | 0 235 ± 0 035(+3 1) | 6 5 ± 0 9(+6 3)
400 + 100 | 10 | 35 53 | 2 818 ± 0 357(+68 0)^**^ | 79 2 ± 4 5(+78 5)^**^ | 0 213 ± 0 032(−6 6) | 6 0 ± 1 0(−0 8)
0 + 200 | 10 | 35 71 | 3 519 ± 0 532(+109 8)^**^ | 98 3 ± 9 8(+121 6)^**^ | 0 233 ± 0 048(+2 3)^d^ | 6 5 ± 1 4(+7 0)
100 + 200 | 9 | 34 12^*^ | 3 151 ± 0 342(+87 9)^**^ | 92 3 ± 7 2(+108 3)^**^ | 0 208 ± 0 024(−8 9) | 6 1 ± 0 6(+0 2)
200 + 200 | 9 | 32 69^**^ | 2 980 ± 0 126(+77 7)^**^ | 90 6 ± 3 0(+104 3)^**^ | 0 209 ± 0 045(−8 4) | 6 4 ± 1 4(+4 6)
400 + 200 | 3 | 34 87 | 3 183 ± 0 091 (+89 8)^**^ | 91 4 ± 4 3(+106)^**^ | 0 203 ± 0 012(−10 8) | 5 8 ± 0 3(−4 1)
0 + 400 | 10 | 32 50^**^ | 4 184 ± 0 239(+149 5)^**^ | 128 9 ± 7 6(+190 6)^**^ | 0 196 ± 0 031(−14 0) | 6 0 ± 0 9(−0 8)
100 + 400 | 2 | 30 25^**^ | 3 810 ± 0 509(+127 2)^**^ | 125 7 ± 4 8(+183 5)^**^ | 0 160 ± 0 000(−99 8)^*^ | 5 3 ± 0 5(−12 6)
200 + 400 | 1 | 22 70^**^ | 2 680(+59 8)^**^ | 118 1(+166 3)^**^ | 0 130(−43 0)^*^ | 5 7(−5 8)
| | | Right Testicle | | Thymus
0 + 0 | 10 | 37 71 | 0 118 ± 0 011 | 3 2 ± 0 5 | 0 036 ± 0 004 | 1 0 ± 0 1
100 + 0 | 10 | 38 32 | 0 117 ± 0 009(−1 1) | 3 1 ± 0 5(−2 3) | 0 034 ± 0 005(−6 3) | 0 9 ± 0 1(−8 2)
200 + 0 | 10 | 34 66^**^ | 0 113 ± 0 005(−4 3) | 3 3 ± 0 2(+3 3) | 0 030 ± 0 004(−17 9)^**^ | 0 9 ± 0 1(−10 7)
400 + 0 | 10 | 36 05 | 0 112 ± 0 009(−5 5) | 3 1 ± 0 3(−2 0) | 0 034 ± 0 004(−6 7)^e^ | 1 0 ± 0 2(−1 0)
0 + 100 | 10 | 35 00^**^ | 0 119 ± 0 010(+0 3) | 3 4 ± 0 2(+6 8) | 0 035 ± 0 003(−3 0) | 1 0 ± 0 1(+3 6)
100 + 100 | 10 | 35 88 | 0 109 ± 0 007(−7 5)^*^ | 3 0 ± 0 2(−3 9) | 0 034 ± 0 007(−7 4) | 0 9 ± 0 2(−3 2)
200 + 100 | 10 | 36 32 | 0 114 ± 0 008(−3 6) | 3 1 ± 0 3(−1 0) | 0 034 ± 0 004(−6 9) | 0 9 ± 0 1(−4 3)
400 + 100 | 10 | 35 53 | 0 103 ± 0 008(−13 2)^**^ | 2 9 ± 0 4(−8 2) | 0 032 ± 0 005(−10 7) | 0 9 ± 0 1(−5 8)
0 + 200 | 10 | 35 71 | 0 115 ± 0 010(−2 4) | 3 2 ± 0 4(+2 3) | 0 037 ± 0 003(+1 1) | 1 0 ± 0 1(+6 5)
100 + 200 | 9 | 34 12^*^ | 0 111 ± 0 008(−6 4) | 3 3 ± 0 3(+2 6) | 0 034 ± 0 003(−6 6) | 1 0 ± 0 1(+2 4)
200 + 200 | 10 | 32 69^**^ | 0 107 ± 0 014(−9 7)^**^ | 3 3 ± 0 4(+3 1) | 0 032 ± 0 004(−13 2)^*^ | 1 0 ± 0 1(−0 5)
400 + 200 | 3 | 34 87 | 0 098 ± 0 009(−17 0)^**^ | 2 8 ± 0 3(−11 3) | 0 028 ± 0 006(−22 9)^**^ | 0 8 ± 0 2(−17 1)
0 + 400 | 10 | 32 50^**^ | 0 108 ± 0 011(−8 9)^*^ | 3 3 ± 0 3(+4 3) | 0 034 ± 0 007(−5 5) | 1 1 ± 0 2(+8 8)
100 + 400 | 2 | 30 25^**^ | 0 088 ± 0 003(−25 5)^**^ | 2 9 ± 0 2(−8 0) | 0 022 ± 0 006(−39 4)^**^ | 0 7 ± 0 1(−25 7)^*^
200 + 400 | 1 | 22 70^**^ | 0 070(−40 0) | 3 1(−2 7) | —^f^ | —
Female
| | | Heart | | Right Kidney
0 + 0 | 10 | 28 89 | 0 125 ± 0 010 | 4 4 ± 0 4 | 0 189 ± 0 023 | 6 6 ± 0 5
100 + 0 | 10 | 26 95 | 0 112 ± 0 010(−10 4)^*^ | 4 2 ± 0 5(−4 4) | 0 172 ± 0 015(−9 0)^*^ | 6 4 ± 0 7(−2 5)
200 + 0 | 10 | 28 39 | 0 119 ± 0 009(−4 8) | 4 2 ± 0 3(−3 6) | 0 184 ± 0 016(−2 6) | 6 5 ± 0 7(−0 8)
400 + 0 | 10 | 27 73 | 0 120 ± 0 013(−4 0) | 4 4 ± 0 5(−0 2) | 0 184 ± 0 017(−2 6) | 6 7 ± 0 7(+1 5)
0 + 100 | 10 | 29 86 | 0 123 ± 0 008(−1 6) | 4 1 ± 0 3(−5 6) | 0 195 ± 0 019(+3 2) | 6 5 ± 0 5(−0 6)
100 + 100 | 9 | 28 38 | 0 128 ± 0 012(+2 2) | 4 6 ± 0 6(+4 3) | 0 188 ± 0 014(−0 6) | 6 7 ± 0 6(+1 6)
200 + 100 | 10 | 29 03 | 0 127 ± 0 125(+1 6) | 4 4 ± 0 3(+0 3) | 0 190 ± 0 018(+0 5) | 6 6 ± 0 3(−0 3)
400 + 100 | 7 | 26 96 | 0 141 ± 0 023(+13 1)^**^ | 5 4 ± 0 8(+24 7)^**^ | 0 201 ± 0 026(+6 6) | 7 5 ± 0 5(+14 3)^**^
0 + 200 | 10 | 27 72 | 0 117 ± 0 007(−6 4) | 4 2 ± 0 3(−2 9)^*^ | 0 190 ± 0 008(+0 5) | 6 9 ± 0 5(+4 8)
100 + 200 | 10 | 25 53^*^ | 0 143 ± 0 021(+14 7)^**^,^d^ | 5 8 ± 1 7(+32 5)^**^ | 0 186 ± 0 026(−1 6) | 7 4 ± 0 9(+11 9)^**^
200 + 200 | 4 | 24 08^**^ | 0 180 ± 0 010(+44 0)^**^,^g^ | 7 3 ± 0 9(+68 0)^**^ | 0 200 ± 0 014(+5 8) | 8 4 ± 1 2(+27 5)^**^
0 + 400 | 10 | 28 13 | 0 114 ± 0 007(−8 8)^*^ | 4 1 ± 0 3(−7 1) | 0 186 ± 0 012(−1 6) | 6 6 ± 0 5(+0 7)
| | | Liver | | Lung
0 + 0 | 10 | 28 89 | 1 240 ± 0 168d^c^ | 42 4 ± 3 4 | 0190 ± 0 021 | 6 6 ± 0 8
100 + 0 | 10 | 26 95 | 1 093 ± 0 091(−11 9)^d^ | 40 3 ± 3 3(−5 0) | 0 176 ± 0 025(−7 2)^e^ | 6 5 ± 0 9(−1 9)
200 + 0 | 10 | 28 39 | 1 163 ± 0 110(−6 2) | 41 0 ± 2 6(−3 2) | 0 170 ± 0 023(−10 5) | 6 0 ± 0 9(−9 2)
400 + 0 | 10 | 27 73 | 1 214 ± 0 137(−2 1) | 43 9 ± 4 4(+3 6) | 0 190 ± 0 049(+0 0) | 6 9 ± 1 8(+3 9)
0 + 100 | 10 | 29 86 | 1 723 ± 0 118(+38 9)^**^ | 57 7 ± 2 2(+36 1)^**^ | 0 178 ± 0 018(−6 3) | 6 0 ± 0 6(−10 0)
100 + 100 | 9 | 28 38 | 1 772 ± 0 314(+42 9)^**^ | 62 4 ± 6 5(+47 1)^**^ | 0 181 ± 0 018(−4 7) | 6 5 ± 1 0(−2 5)
200 + 100 | 10 | 29 03 | 1 690 ± 0 163(+36 3)^**^ | 58 2 ± 1 5(+37 3)^**^ | 0 168 ± 0 015(−11 6) | 5 8 ± 0 6(−12 3)
400 + 100 | 7 | 26 96 | 1 659 ± 0 228(+33 7)^**^ | 61 6 ± 2 1(+45 0)^**^ | 0 174 ± 0 029(−8 3) | 6 5 ± 1 0(−1 6)
0 + 200 | 10 | 27 72 | 2 051 ± 0 209(+65 4)^**^ | 74 1 ± 5 3(+74 7)^**^ | 0 186 ± 0 038(−2 3)^d^ | 6 6 ± 1 6(+0 1)
100 + 200 | 10 | 25 53^*^ | 2 068 ± 0 344(+66 7)^**^ | 81 1 ± 5 0(+91 2)^**^ | 0 152 ± 0 014(−20 0)^**^ | 6 0 ± 0 8(−8 8)^*^
200 + 200 | 4 | 24 08^**^ | 1 988 ± 0 083(+60 2)^**^ | 82 9 ± 6 6(+95 6)^**^ | 0 163 ± 0 015(−14 5) | 6 8 ± 0 4(+1 9)
0 + 400 | 10 | 28 13 | 3 353 ± 0 098(+170 3)^**^ | 119 2 ± 4 1(+181 2)^**^ | 0 173 ± 0 017(−8 9) | 6 2 ± 0 6(−7 2)
| | | Thymus
0 + 0 | 9 | 28 89 | 0 039 ± 0 007 | 1 4 ± 0 3
100 + 0 | 10 | 26 95 | 0 041 ± 0 005(+5 0) | 1 5 ± 0 2(+10 1)
200 + 0 | 10 | 28 39 | 0 038 ± 0 004(−2 0) | 1 3 ± 0 2(−l 9)
400 + 0 | 10 | 27 73 | 0 039 ± 0 005(−0 4) | 1 4 ± 0 1(+1 5)
0 + 100 | 9 | 29 86 | 0 043 ± 0 005(+12 1) | 1 5 ± 0 2(+6 7)
100 + 100 | 9 | 28 38 | 0 037 ± 0 005(−5 2) | 1 3 ± 0 2(−4 7)
200 + 100 | 10 | 29 03 | 0 038 ± 0 005(−0 9)^*^ | 1 3 ± 0 2(−3 2)
400 + 100 | 7 | 26 96 | 0 034 ± 0 005(−12 1) | 1 2 ± 0 2(−11 7)
0 + 200 | 10 | 27 72 | 0 039 ± 0 006(+1 4) | 1 4 ± 0 3(+4 7)
100 + 200 | 10 | 25 53^*^ | 0 030 ± 0 010(−22 4)^**^ | 1 1 ± 0 3(−16 2)^*^
200 + 200 | 4 | 24 08^**^ | 0 023 ± 0 008(−39 7)^**^ | 0 9 ± 0 3(−32 1)^**^
0 + 400 | 10 | 28 13 | 0 038 ± 0 006(−l 5) | 1 4 ± 02(−l 1)

* Significantly different (P≤0.05) from vehicle control by Student’s t-test for organ and body weights and by Jonckheere’s and Williams’ or Dunnett’s tests for body weights

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b n=number examined

c Data are presented as mean value ± standard deviation (% difference from control)

d n=9

e n=8

f n=0, single available weight excluded as outher

g n=3

FIGURE 1 Mean Body Weights of Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(*All animals in this group died early)

FIGURE 2 Mean Body Weights of Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(*All animals in this group died early)

Administration of rifampicin alone caused greater declines in final mean body weights of male mice than of female mice (Table 3 and Figures 1 and 2). Respective final mean body weights of male mice treated with 100, 200, or 400 mg of rifampicin were approximately 7% (35.00 grams; P≤0.05), 5% (35.71 grams), and 14% (32.50 grams; P≤0.01) lower than the mean (37.71) of the control group. Female mice treated with 100 mg of rifampicin alone did not have lower body weights. Respective final mean body weights of female groups treated with 200 or 400 mg of rifampicin alone were approximately 4% (27.72 grams) and 3% (28.13 grams) lower than the mean (28.89 grams) of the female control group.

Treatment with 100, 200, or 400 mg of AZT in combination with 100 mg of rifampicin had no impact on body weight gain or final mean body weights of male or female mice (Table 3 and Figures 1 and 2). Male and female groups treated with combination therapy at higher dosages had mean body weights at least 10% lower than body weights of the corresponding control groups. Lower body weights were evident in higher dosage combination groups by day 30. Male groups treated with 100 or 200 mg AZT + 400 mg rifampicin and 400 mg AZT + 200 mg rifampicin had marked decreases in body weights by 6 to 7 weeks and marked recovery in body weights by 8 to 11 weeks. Due to anemia, a number of mice in these groups lost weight and died by week 8. The surviving mice had higher body weights than the mice that died, and the surviving mice showed some recovery in growth resulting in the marked increases in body weights from week 8 to week 11 of the study. Respective final mean body weights for male groups treated with 100 or 200 mg of AZT in combination with 200 mg of rifampicin were approximately 10% (34.12 grams; P≤0.05) and 13% (32.69 grams; P≤0.01) lower than the mean (37.71 grams) of the male control group. The final mean body weight of two surviving male mice treated with 100 mg of AZT + 400 mg of rifampicin was approximately 20% (30.25 grams; P≤0.01) lower than that of the control group (37.71 grams). The final body weight of the single surviving mouse treated with 200 mg of AZT + 400 mg of rifampicin was approximately 40% (22.70 grams; P≤0.01) lower than the mean of the male control group (37.71 grams). Final body weights were not available for the male group treated with 400 mg of AZT + 400 mg of rifampicin due to mortality. For the female group treated with 100 mg of AZT in combination with 200 mg of rifampicin, the final mean body weight was approximately 12% (25.53 grams; P≤0.05) lower than the mean (28.89 grams) of the control group. The final mean body weight of female mice treated with 200 mg of AZT + 200 mg of rifampicin was approximately 17% (24.07 grams; P≤0.01) lower than the mean (28.89 grams) of the controls. Female mice treated with higher combinations did not survive.

Marked increases in absolute and relative liver weights occurred in male and females treated with rifampicin alone, and these increases were dose related (Table 3 and Figure 3). Respective absolute mean liver weights for male mice treated with 100, 200, or 400 mg of rifampicin were approximately 1.5, 2.0, and 2.5 times (P≤0.01) the mean of the control group. For the female mice receiving the same doses, respective mean liver weights were approximately 1.4, 1.7, and 2.7 times the mean of the female control group (P≤0.01). The dose-related increases in liver weights corresponded well with elevated serum enzymes indicative of hepatotoxicity. Administration of AZT alone to male and female mice had no impact on liver weights. Treatment with combinations of AZT and rifampicin caused increases in liver weights comparable to the increases observed in mice treated with rifampicin alone.

FIGURE 3 Mean Absolute Liver Weights of Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* No data available due to mortality)

Administration of AZT alone or rifampicin alone did not result in dose-related alterations in thymus weights (Table 3). Treatment-related decreases in absolute thymus weights did occur in mice treated with higher concentration combinations of AZT and rifampicin, and the decreased thymus weights corresponded with thymic atrophy. Respective mean thymus weights of male groups treated with 200 or 400 mg of AZT in combination with 200 mg of rifampicin were approximately 13% (P≤0.05) and 23% lower (P≤0.01) than the mean of the male control group. Male mice treated with 100 mg of AZT and 400 mg of rifampicin had a mean thymus weight approximately 40% lower (P≤0.01) than the mean weight of the control group. Respective mean thymus weights in female mice treated with 100 and 200 mg of AZT in combination with 200 mg of rifampicin were approximately 22% and 40% lower (P≤0.01) than the mean of the female control group.

Increases in absolute and/or relative heart weights were observed in male and female mice treated with higher concentration combinations of AZT and rifampicin (Table 3). These elevated heart weights occurred in groups that were anemic and may reflect a compensatory physiological hypertrophy brought on by chronic increased heart rate or force of contraction in an attempt to oxygenate the body. Respective mean relative heart weights in male groups treated with 200 or 400 mg of AZT in combination with 200 mg of rifampicin were approximately 1.1 and 1.3 times (P≤0.01) that of the male controls. For the two surviving male mice treated with 100 mg of AZT + 400 mg of rifampicin, the mean relative heart weight was approximately 1.3 times (P≤0.01) the mean of the control group. The single surviving male mouse treated with 200 mg of AZT + 400 mg of rifampicin had a relative heart weight approximately 2.3 times (P≤0.01) the control group mean. Mean relative heart weights in female mice treated with 400 mg of AZT + 100 mg of rifampicin were approximately 1.2 times (P≤0.01) the mean of the female control group. Respective mean relative heart weights in female mice treated with 100 and 200 mg of AZT in combination with 200 mg of rifampicin were approximately 1.3 and 1.6 times (P≤0.01) the mean of the female control group. In general, significant decreases (P≤0.05 or P≤0.01) in absolute heart weights of male mice treated with 200 or 400 mg of rifampicin alone and female groups treated with 100 mg of AZT alone and 400 mg of rifampicin alone paralleled decreases in body weights.

Significantly lower (P≤0.05 or P≤0.01) testicular weights were observed in male groups treated with 400 mg of rifampicin alone, 100 mg of AZT + 100 or 400 mg of rifampicin, 200 mg of AZT + 200 or 400 mg of rifampicin, and 400 mg of AZT + 100 or 200 mg of rifampicin (Table 3). In general, testis weights decreased with increasing doses of rifampicin.

Significant (P≤0.05) changes in absolute or relative kidney and lung weights observed in some male and female groups (Table 3) were not considered to be biologically significant because the changes generally paralleled decreases in final mean body weights and histopathological lesions were not observed.

## Clinical Pathology

### Hematology

#### AZT Alone

Administration of AZT alone at 100, 200, or 400 mg/kg per day caused anemia, reticulocytopenia followed by reticulocytosis, thrombocytosis, and leukopenia. In general, changes were more prevalent in females than in males. The anemic process was mild, usually dose-related, and accompanied by elevations in mean cell volume (MCV) and mean cell hemoglobin (MCH) values, and as such, could be classified as macrocytic. Hematology values are given in Appendix A.

On day 4, significant alterations in red blood cell (RBC) counts did not occur in male mice (Figure 4) treated with AZT alone. Significant alterations did occur, however, in female mice treated with AZT alone. Respective mean RBC counts on day 4 of female mice (Figure 5) treated with 100, 200, or 400 mg of AZT were approximately 6% (9.11 × 10^6^/mm^3^; P≤0.01), 4% (9.30 × 10^6^/mm^3^; P≤0.05), and 4% (9.38 × 10^6^/mm^3^) lower than the mean RBC count (9.73 × 10^6^ mm^3^) of the female control group. Significant alterations did not occur in MCV, MCH, or mean cell hemoglobin concentration (MCHC) values on day 4, but slight declines in hemoglobin (Hgb) and hematocrit (Hct) accompanied the lower RBC counts.

On day 30, a marginal anemia occurred in male and female mice treated with AZT alone. Respective mean RBC counts on day 30 for male mice (Figure 4) treated with 100, 200, or 400 mg of AZT were approximately 10% (8.63 × 10^6^/mm^3^), 14% (8.32 × 10^6^/mm^3^; P≤0.05), and 16% (8.06 × 10^6^/mm^3^; P≤0.01) lower than the mean RBC count (9.64 × 10^6^/mm^3^) of the male control group. Declines in Hgb (Figure 6) and Ret values paralleled the decreases in RBC counts. Elevations in MCV and MCH values also accompanied the dose-related anemia. Respective mean MCV values for male mice treated with 100, 200, or 400 mg of AZT were approximately 8% (52.9 fL; P≤0.01), 11% (54.1 fL); P≤0.01), and 14% (55.7 fL; P≤0.01) higher than the mean (48.8 fL) of the male control group. Similar alterations occurred on day 30 in female mice treated with AZT alone. Respective mean RBC counts on day 30 for female mice (Figure 5) treated with 100, 200, or 400 mg of AZT were approximately 10% (8.28 × 10^6^/mm^3^), 14% (7.97 × 10^6^/mm^3^; P≤0.01), and 13% (8.04 × 10^6^/mm^3^; P≤0.05) lower than the mean (9.25 × 10^6^/mm^3^) of the female control group. Marginal decreases in Hgb (Figure 7) and Hct values accompanied the decreases in RBC counts, and slight dose-related elevations in MCV and MCH values also accompanied the anemia. Respective mean MCV values for the female mice treated with 100, 200, or 400 mg were approximately 10% (53.4 fL; P≤0.01), 12% (54.1 fL; P≤0.01), and 15% (55.7 fL; P≤0.01) higher than the mean (48.5 fL) of the female controls.

FIGURE 4 Mean Red Blood Cell Counts for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 5 Mean Red Blood Cell Counts for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 6 Mean Hemoglobin Values for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 7 Mean Hemoglobin Values for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

On day 60, the severity of the anemic process was greater than on day 30. Respective mean RBC counts on day 60 of male mice (Figure 4) were approximately 14% (8.77 × 10^6^/mm^3^; P≤0.01), 18% (8.34 × 10^6^/mm^3^; P≤0.01), and 21% (7.99 × 10^6^/mm^3^; P≤0.01) lower than the mean (10.16 × 10^6^/mm^3^) of the male control group. Decreased Hgb (Figure 6) and Hct values accompanied the dose-related declines in RBC counts. Dose-related elevations in MCV and MCH values also accompanied the anemia. Respective mean MCV values for male mice treated with 100, 200, or 400 mg of AZT were approximately 9% (51.2 fL; P≤0.01), 14% (53.7 fL; P≤0.01), and 17% (54.8 fL; P≤0.01) higher than the mean MCV value (47.0 fL) of the male control group. Similar trends occurred on day 60 in female mice treated with AZT alone; however, the severity of the alterations was greater. Respective mean RBC counts on day 60 of female mice (Figure 5) treated with 100, 200, or 400 mg of AZT alone were approximately 20% (8.18 × 10^6^/mm^3^; P≤0.01), 24% (7.76 × 10^6^/mm^3^; P≤0.01), and 28% (7.42 × 10^6^/mm^3^; P≤0.01) lower than the mean RBC count (10.24 × 10^6^/mm^3^) of the female control group. Declines in Hgb (Figure 7) and Hct values paralleled the dose-related decreases in RBC counts. Dose-related elevations in MCV and MCHvalues were also prominent. Respective mean MCV values for female mice treated with 100, 200, or 400 mg of AZT were approximately 13% (53.4 fL; P≤0.01), 18% (55.9 fL; P≤0.01), and 22% (57.8 fL; P≤0.01) higher than the mean (47.3 fL) of the female control group.

At the time of terminal sacrifice on days 92 to 95, alterations in RBC values were similar to those observed on day 60. Respective mean RBC counts on days 92 to 95 in male mice (Figure 4) treated with 100, 200, or 400 mg of AZT alone were approximately 15% (8.40 × 10^6^/mm^3^; P≤0.01), 19% (8.01 × 10^6^/mm^3^; P≤0.01) and 25% (7.41 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.86 × 10^6^/mm^3^) of the control group. Lower Hgb (Figure 6) and Hct values paralleled the dose-related declines in RBC counts. Treatment-related elevations in MCV and MCH values also occurred. Respective mean MCV values for the 100, 200, and400 mg groups were approximately 13% (52.7 fL; P≤0.01), 19% (55.7 fL; P≤0.01), and22% (57.2 fL; P≤0.01) higher than the mean (46.7 fL) of the male control group. The severity of the anemia was slightly greater in female mice than in males. Respective mean RBC counts on days 92 to 95 in female mice (Figure 5) treated with 100, 200, or 400 mg of AZT alone were approximately 19% (7.95 × 10^6^/mm^3^; P≤0.01), 25% (7.40 × 10^6^/mm^3^; P≤0.01), and 30% (6.88 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.85 × 10^6^/mm^3^) of the female control group. Decreases in Hgb (Figure 7) and Hct values paralleled the dose-related declines in RBC counts. Elevations in MCV and MCH values also accompanied the anemia. Respective mean MCV values for the 100, 200, and 400 mg female groups were approximately 15% (54.4 fL; P≤0.01), 23% (57.9 fL; P≤0.01), and 27% (59.6 fL; P≤0.01) higher than the mean (47.1 fL) of the female controls.

Administration of AZT alone to male and female mice also produced statistically and biologically significant alterations in reticulocyte counts (Figures 8 and 9). Initially, a reticulocytopenia developed and was followed by a reticulocytosis later in the study. Respective mean reticulocyte counts on day 4 in male mice (Figure 8) treated with 100, 200, or 400 mg of AZT alone were approximately 25% (2.7 × 10^5^/mm^3^; P≤0.01), 31% (2.5 × 10^5^/mm^3^; P≤0.01), and 42% (2.1 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.6 × 10^5^/mm^3^) of the male control group. For the female groups (Figure 9) treated identically, respective mean reticulocyte counts were approximately 58% (1.3 × 10^5^/mm^3^; P≤0.01), 52% (1.5 × 10^5^/mm^3^; P≤0.01), and 55% (1.4 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.1 × 10^5^/mm^3^) of the control group. Reticulocyte counts rebounded in both males and females, as significant (P≤0.05) alterations in reticulocyte counts did not occur on day 30 in male or female mice treated with AZT alone. On day 60, mild elevations in reticulocyte counts occurred. Respective mean reticulocyte counts on day 60 in male mice (Figure 8) treated with 200 or 400 mg of AZT were approximately 1.2 times (4.2 × 10^5^/mm^3^; P≤0.01) and 1.3 times (4.5 × 10^5^/mm^3^; P≤0.01) the mean (3.6 × 10^5^/mm^3^) of the male control group. Although not statistically significant, respective mean reticulocyte counts for female mice (Figure 9) treated identically were approximately 1.2 times (4.3 × 10^5^/mm^3^) and 1.2 times (4.4 × 10^5^/mm^3^) the mean (3.5 × 10^5^/mm^3^) of the female control group. At the termination of the study on days 92 to 95, reticulocytosis was not evident in male mice treated with AZT alone. Forthe female mice (Figure 9), however, respective mean reticulocyte counts in the 200 and 400 mg groups were approximately 1.4 times (5.2 × 10^5^/mm^3^) and 1.5 times (5.4 × 10^5^/mm^3^; P≤0.05) the mean (3.7 × 10^5^/mm^3^) of the female control group.

Thrombocytosis also occurred in male and female mice treated with AZT alone (Figures 10 and 11). On day 30, respective mean platelet counts in female mice (Figure 11) treated with 100, 200, or 400 mg of AZT alone were approximately 1.1 times (1,282 × 10^3^/mm^3^), 1.3 times (1,412 × 10^3^/mm^3^; P≤0.05), and 1.2 times (1,404 × 10^3^/mm^3^) the mean (1,129 × 10^3^/mm^3^) of the female control group. Platelet counts in the corresponding male groups (Figure 10) were within normal limits on day 30. On day 60, respective mean platelet counts in male mice (Figure 10) in the 100, 200, and 400 mg groups were approximately 1.1 times (1,216 × 10^3^/mm^3^), 1.3 times (1,384 × 10^3^/mm^3^; P≤0.01), and 1.4 times (1,520 × 10^3^/mm^3^; P≤0.01) higher than the mean (1,073 × 10^3^/mm^3^) of the male control group. Platelet counts in the female groups (Figure 11) were within a normal range on day 60. At the time of terminal sacrifice, alterations in platelet counts did not occur in male mice (Figure 10) treated with AZT alone. For the female mice (Figure 11) treated with 200 or 400 mg of AZT, respective platelet counts were approximately 1.4 times (1,331 × 10^3^/mm^3^; P≤0.01) and 1.4 times (1,319 × 10^3^/mm^3^; P≤0.01) the mean (975 × 10^3^/mm^3^) of the female control group at the time of terminal sacrifice.

FIGURE 8 Mean Reticulocyte Counts for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 9 Mean Reticulocyte Counts for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 10 Mean Platelet Counts for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 11 Mean Platelet Counts for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

Macrocytic anemia, reticulocytopenia followed by reticulocytosis, and thrombocytosis that occurred subsequent to the administration of AZT were all similar to those previously described in mice (Thompson et al., 1991).

#### Rifampicin Alone

Administration of rifampicin alone at 100, 200, or 400 mg/kg per day caused anemia, reticulocytopenia, and occasional neutrophilia. In general, the anemia was mild and dose related, with reductions in Hgb values of greater magnitude than reductions in RBC counts. The slight anemia was accompanied by dose-related declines in MCV and MCH values and could be classified as microcytic. Hematology values are listed in Appendix A.

On day 4, statistically or biologically significant alterations did not occur in male or female mice treated with rifampicin alone. On day 30, mild declines in Hgb, Hct, MCV, and MCH occurred in male and female mice treated with 400 mg of rifampicin without biologically significant declines in RBC counts. Respective mean Hgb values in male and female mice (Figures 6 and 7) treated with 400 mg of rifampicin were approximately 7% (14.7 g/dL and 13.8 g/dL) lower than the mean Hgb values of the corresponding control groups (15.8 g/dL and 14.9 g/dL). Corresponding mean MCV values for male and female mice treated with 400 mg were approximately 5% (46.3 fL) and 6% (45.8 fL) lower than the mean of the male and female control groups (48.8 fL and 48.5 fL). Significant declines (P≤0.01) in corresponding MCH values occurred, with respective mean MCH values approximately 5% (15.6 pg) and 6% (15.1 pg) lower than the means of the male and female control groups (16.4 pg and 16.1 pg). The decreases in Hgb, Hct, MCV, and MCH indicate a hematological microcytic response even though RBC counts were not significantly decreased.

On day 60, a distinct dose-related anemia was evident in male and female mice treated with rifampicin alone, and the severity of the anemia was most evident in the Hgb parameter. Respective mean Hgb values on day 60 in male mice (Figure 6) treated with 100, 200, or 400 mg of rifampicin were approximately 5% (15.8 g/dL; P≤0.01), 10% (15.1 g/dL; P≤0.01), and 15% (14.2 g/dL; P≤0.01) lower than the mean (16.7 g/dL) of the male control group. Corresponding RBC counts (Figure 4) were approximately 1% (10.06 × 10^6^/mm^3^), 4% (9.79 × 10^6^/mm^3^), and 7% (9.55 × 10^6^/mm^3^; P≤0.01) lower than the mean RBC count (10.16 × 10^6^/mm^3^) of the male control group. Declines in Hct values accompanied the lower Hgb and RBC values. Dose-related declines in MCV and MCH values depicting the microcytic nature of the anemia also occurred. Respective mean MCV values on day 60 in male mice treated with 100, 200, or 400 mg of rifampicin were approximately 3% (45.6 fL; P≤0.01), 4% (45.0 fL; P≤0.01), and 8% (43.4 fL; P≤0.01) lower than the mean (47.0 fL) of the male control group. A dose-related microcytic anemia of similar severity also occurred on day 60 in female mice treated with rifampicin alone. Respective Hgb values in female mice (Figure 7) treated with 100, 200, or 400 mg of rifampicin were approximately 11% (14.6 g/dL), 12% (14.5 g/dL), and 16% (13.7 g/dL; P≤0.05) lower than the mean (16.4 g/dL) of the control group. Corresponding RBC counts (Figure 5) for the same treatment groups were approximately 11% (9.15 × 10^6^/mm^3^), 8% (9.39 × 10^6^/mm^3^), and 9% (9.34 × 10^6^/mm^3^) lower than the mean (10.24 × 10^6^/mm^3^) of the female control group. Lower Hct values accompanied the declines in Hgb and RBC values. Although not statistically significant (P≤0.05), declines in MCV values occurred in the 200 and 400 mg groups. Respective MCV values were approximately 3% (45.9 fL) and 6% (44.4 fL) lower than the mean of the female control group. Corresponding MCH values for the 200 and 400 mg female groups were approximately 4% (15.4 pg; P≤0.01) and 9% (14.6 pg; P≤0.01) lower than the mean (16.0 pg) of the control.

At the end of the study, on days 92 to 95, the severity of the microcytic anemia was slightly greater than at day 60. Respective mean Hgb values for male mice treated with 100, 200, or 400 mg of rifampicin (Figure 6) were approximately 4% (14.9 g/dL), 8% (14.2 g/dL; P≤0.05), and 21% (12.3 g/dL) lower than the mean (15.5 g/dL) of the male control group. Declines in RBC counts (Figure 4) were not observed in the male groups treated with 100 or 200 mg of rifampicin. However, the mean RBC count in the 400 mg male group was approximately 10% (8.84 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.86 × 10^6^/mm^3^) of the control group. Declines in Hct values paralleled the decreases in Hgb values. Respective mean MCV values for male mice treated with 100, 200, or 400 mg of rifampicin were approximately 4% (45.0 fL), 7% (43.4 fL; P≤0.01), and 7% (43.3 fL; P≤0.01) lower than the mean (46.7 fL) of the male control group. Similar alterations occurred in female mice at the end of the study. Respective mean Hgb values (Figure 7) in female mice treated with identical doses of rifampicin were approximately 8% (14.4 g/dL), 11% (13.9 g/dL), and 20% (12.5 g/dL) lower than the mean (15.6 g/dL) of the female control group. Corresponding RBC counts (Figure 5) were approximately 5% (9.31 × 10^6^/mm^3^), 6% (9.21 × 10^6^/mm^3^), and 11% (8.77 × 10^6^/mm^3^; P≤0.05) lower than the mean (9.85 × 10^6^/mm^3^) of the female control group. Declines in Hct values accompanied the decreases in Hgb and RBC values. Declines in MCV and MCH values typical of a microcytic anemia also occurred in the 400 mg female treatment group. The mean MCV value was approximately 7% (43.9 fL; P≤0.05) lower than the mean (47.1 fL) of the control group, and the mean MCH value was approximately 10% (14.3 pg; P≤0.01) lower than the mean (15.9 pg) of the control.

A distinct dose-related reticulocytopenia was observed in male and female mice treated with rifampicin alone. On day 4, respective mean reticulocyte counts in male mice (Figure 8) treated with 100, 200, or 400 mg of rifampicin were approximately 31% (2.5 × 10^5^/mm^3^; P≤0.01), 47% (1.9 × 10^5^/mm^3^; P≤0.01), and 61% (1.4 × 10^5^/mm^3^; P≤0.01) lower than the mean reticulocyte count (3.6 × 10^5^/mm^3^) of the male control group. Respective mean reticulocyte counts on day 4 in female mice (Figure 9) treated with same doses were approximately 42% (1.8 × 10^5^/mm^3^; P≤0.01), 65% (1.1 × 10^5^/mm^3^; P≤0.01), and 77% (0.7 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.1 × 10^5^/mm^3^) of the female control group. Reticulocyte counts rebounded in all treatment groups of both males and females as statistically significant (P≤0.05) alterations did not occur on day 30. On day 60, significant declines (P≤0.05) in mean reticulocyte counts were observed in male (Figure 8) and female (Figure 9) mice treated with 400 mg of rifampicin alone. Respective mean reticulocyte counts for male and female mice in the 400 mg/kg group were approximately 19% (2.9 × 10^5^/mm^3^; P≤0.05) and 46% (1.9 × 10^5^/mm^3^; P≤0.05) lower than the respective means (3.6 × 10^5^/mm^3^ and 3.5 × 10^5^/mm^3^) of the male and female control groups. At the end of the study, significant (P≤0.05) declines in reticulocyte counts did not occur in male or female groups treated with rifampicin alone.

Male and female mice treated with rifampicin alone tended to have minor treatment-related elevations in segmented neutrophil counts. This compound-related neutrophilia was statistically significant on day 30 in female mice and on day 60 in male mice. On day 60, respective mean neutrophil counts in male mice (Figure 12) treated with 100, 200, or 400 mg of rifampicin alone were approximately 1.6 times (0.81 × 10^3^/mm^3^; P≤0.01), 1.5 times (0.78 × 10^3^/mm^3^; P≤0.05), and 1.5 times (0.79 × 10^3^/mm^3^; P≤0.05) the mean (0.52 × 10^3^/mm^3^) of the male control group. On day 30, respective mean neutrophil counts of female mice (Figure 13) treated with 200 or 400 mg of rifampicin alone were approximately 1.6 times (0.93 × 10^3^/mm^3^; P≤0.01) and 1.9 times (1.11 × 10^3^/mm^3^; P≤0.01) the mean neutrophil count (0.60 × 10^3^/mm^3^) of the female control group. Although not statistically significant, total WBC counts were slightly elevated (Figures 14 and 15), reflecting the impact of the neutrophilia.

A slightly significant (P≤0.05) elevation in platelet counts on day 4 in the 200 mg rifampicin female group (Figure 11) was not considered to be biologically significant, as a dose-related pattern was not observed. No other statistically significant (P≤0.05) alterations in platelet counts occurred in male or female mice treated with rifampicin alone.

Treatment with rifampicin alone resulted in a dose-related microcytic anemia in contrast to the macrocytic anemia caused by AZT. The microcytic anemia was accompanied by an early reticulocytopenia that tended to rebound by day 30. However, rifampicin-associated microcytic anemia did not cause reticulocytosis.

FIGURE 12 Mean Neutrophil Counts for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 13 Mean Neutrophil Counts for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 14 Mean White Blood Cell Counts for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 15 Mean White Blood Cell Counts for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

#### AZT and Rifampicin Combinations

In general, administration of combinations of AZT and rifampicin to male and female mice resulted in hematological alterations of far greater severity than those caused by either drug alone. In general, effects in female mice were more severe than in males. Hematology values are given in Appendix A.

On day 4, statistically significant (P≤0.05) alterations in erythrocyte parameters were not observed in male mice treated with AZT and rifampicin combinations. Although overt anemia did not occur, significant (P≤0.01) declines in RBC counts occurred in several female groups (Figure 5) treated with AZT and rifampicin. The lowest RBC count observed in female mice treated with 400 mg of AZT + 200 mg of rifampicin, and it was approximately 7% (9.08 × 10^6^/mm^3^; P≤0.01) lower then the mean (9.73 × 10^3^/mm^3^) of the control group. Approximately 6% decreases occurred in female groups treated with 200 or 400 mg of AZT + 100 mg of rifampicin, 200 mg of AZT + 200 mg of rifampicin, and 200 mg of AZT + 400 mg of rifampicin. Slight decreases in Hgb (Figure 7) and Hct values paralleled the declines in RBC counts.

On day 30, severe dose-related anemia occurred in male and female mice treated with combinations of AZT and rifampicin, and the severity of the anemia contributed to mortality in the 400 mg AZT + 400 mg rifampicin combination groups. The mean RBC count of male mice (Figure 4) treated with 200 mg of AZT + 400 mg of rifampicin was approximately 73% (2.56 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.64 × 10^6^/mm^3^) of the male control group. All male mice treated with 400 mg of AZT + 400 mg of rifampicin had died prior to day 30. The mean RBC count of female mice (Figure 5) treated with 400 mg of AZT + 400 mg of rifampicin was approximately 87% (1.21 × 10^6^/mm^3^) lower than the mean (9.25 × 10^6^/mm^3^) of the vehicle control group. Declines in Hgb (Figures 6 and 7) and Hct values accompanied the lower RBC counts in male and female mice. In general, the anemia was macrocytic in the low-dosage combination groups, reflecting the influence of AZT, and microcytic in the high-dosage combination groups, reflecting the effect of rifampicin. The peak MCV value of males occurred in the group treated with 400 mg of AZT + 100 mg of rifampicin and was approximately 13% (54.9 fL; P≤0.01) higher than the mean (48.8 fL) of the control group. For the females, the peak MCV value occurred in the group treated with 200 mg of AZT + 100 mg of rifampicin and was approximately 15% (55.8 fL; P≤0.01) higher than the mean (48.5 fL) of the female control. The lowest MCV value on day 30 was observed in the female group treated with 400 mg of AZT + 400 mg of rifampicin and was approximately 18% (39.7 fL; P≤0.01) lower than the mean (48.5 fL) of the female control.

On day 60, a dose-related macrocytic anemia was present in male and female mice treated with combinations of AZT and rifampicin, and female mice were more anemic than males. The lowest RBC count in male mice (Figure 4) occurred in the group treated with 400 mg of AZT + 200 mg of rifampicin and was approximately 30% (7.09 × 10^6^/mm^3^; P≤0.01) lower than the mean (10.16 × 10^6^/mm^3^) of the male control group. The lowest RBC count in female mice (Figure 5) occurred in the group treated with 400 mg of AZT + 100 mg of rifampicin and was approximately 59% (4.24 × 10^6^/mm^3^; P≤0.01) lower than the mean (10.24 × 10^6^/mm^3^) of the female control group. The anemia was macrocytic in males and females. The peak MCV value in males occurred in the group treated with 400 mg of AZT + 100 mg of rifampicin and was approximately 18% (55.6 fL; P≤0.01) higher than the mean (47.0 fL) of the male control group. For the females, the peak MCV value was observed in the group treated with 200 mg of AZT + 100 mg of rifampicin and was approximately 22% (57.7 fL; P≤0.01) higher than the mean of the control group. All male mice treated with 200 or 400 mg of AZT + 400 mg of rifampicin died prior to day 60. All female mice treated with 100, 200, or 400 mg of AZT + 400 mg of rifampicin as well as those treated with 400 mg of AZT + 200 mg of rifampicin died prior to day 60. In general, male and female mice that had microcytic anemia on day 30 died prior to day 60.

The compound-related anemia in male and female mice treated with AZT and rifampicin combinations was more severe at the time of terminal sacrifice (days 92 to 95) than at day 60. The RBC count in the single surviving male mouse (Figure 4) treated with 200 mg of AZT and 400 mg of rifampicin was approximately 89% (1.10 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.86 × 10^6^/mm^3^) of the male control group. The mean RBC count in the female group (Figure 5) treated with 200 mg of AZT + 200 mg of rifampicin was approximately 84% (1.56 × 10^6^/mm^3^; P≤0.01) lower than the mean (9.85 × 10^6^/mm^3^) of the female control group. Declines in Hgb (Figures 6 and 7) and Hct values paralleled the decreases in RBC counts. Trends in MCV values similar to those described on day 60 occurred at the time of terminal sacrifice. All female mice treated with 400 mg of AZT + 200 mg of rifampicin and 100, 200, or 400 mg of AZT + 400 mg of rifampicin died prior to terminal sacrifice.

Male and female mice treated with combinations of AZT and rifampicin developed a marked reticulocytopenia early (day 4) in the study, and the severity of this alteration was far greater than that subsequent to the administration of either drug alone. Significant declines (P≤0.01) in reticulocyte counts occurred in all male groups receiving combination therapy. The lowest values (Figure 8) occurred in male groups treated with 100 or 200 mg of AZT + 400 mg of rifampicin and were approximately 78% (0.8 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.6 × 10^5^/mm^3^) of the male control group. Mean reticulocyte counts in the female groups (Figure 9) treated with 400 mg of AZT + 200 mg of rifampicin and 200 mg of AZT + 400 mg of rifampicin were approximately 84% (0.5 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.1 × 10^5^/mm^3^) of the control group. Reticulocyte counts rebounded in male and female groups treated with lower dose combinations. On day 30, the mean reticulocyte count in the male group (Figure 8) treated with 400 mg of AZT + 200 mg of rifampicin was approximately 2.4 times (8.5 × 10^5^/mm^3^; P≤0.01) the mean (3.5 × 10^5^/mm^3^) of the male control group. Although not statistically significant (P≤0.05), the reticulocyte count in the male group treated with 200 mg of AZT + 400 mg of rifampicin was approximately 43% (2.0 × 10^5^/mm^3^) lower than the mean (3.5 × 10^5^/mm^3^) of the control group. All male mice treated with 400 mg of AZT + 400 mg of rifampicin died by day 30. For the female mice (Figure 9) on day 30, significant (P≤0.01) reticulocytosis occurred in only one treatment group. The mean reticulocyte count in the female group treated with 400 mg of AZT + 100 mg of rifampicin (Figure 9) was approximately 3.3 times (11.3 × 10^5^/mm^3^; P≤0.01) the mean (3.4 × 10^5^/mm^3^) of the female control group. Although not statistically significant (P≤0.05), marked declines in reticulocyte counts occurred in female groups treated with 400 mg of AZT + 200 mg of rifampicin as well as the groups treated with 100, 200, or 400 mg of AZT + 400 mg of rifampicin. On day 60, the reticulocyte count of the male group (Figure 8) treated with 400 mg of AZT + 100 mg of rifampicin was approximately 1.5 times (5.5 × 10^5^/mm^3^; P≤0.01) the mean (3.6 × 10^5^/mm^3^) of the male control group. In contrast, the mean reticulocyte count in the male group (Figure 8) treated with 100 mg of AZT + 400 mg of rifampicin was approximately 39% (2.2 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.6 × 10^5^/mm^3^) of the control group. Male mice treated with 200 or 400 mg of AZT + 400 mg of rifampicin died prior to day 60. For the female mice on day 60, statistically significant (P≤0.05) alterations in reticulocyte counts did not occur in any of the surviving groups. All female mice treated with 400 mg of AZT + 200 mg of rifampicin as well as those treated with 100, 200 or 400 mg of AZT + 400 mg of rifampicin died prior to day 60.

At the time of terminal sacrifice (days 92 to 95), significant reticulocytopenia (P≤0.01) was observed in male groups treated with 400 mg of AZT + 200 mg of rifampicin as well as the groups treated with 100 or 200 mg of AZT + 400 mg of rifampicin. The lowest value occurred in the single surviving male mouse (Figure 8) treated with 200 mg of AZT + 400 mg of rifampicin and was approximately 90% (0.5 × 10^5^/mm^3^; P≤0.01) lower than the mean (4.9 × 10^5^/mm^3^) of the male control group. All male mice treated with 400 mg of AZT + 400 mg of rifampicin died prior to day 92. For the female mice at terminal sacrifice (days 92 to 95), elevated reticulocyte counts occurred in the low dose combination groups. The mean reticulocyte count of the female group (Figure 9) treated with 200 mg of AZT + 100 mg of rifampicin was approximately 1.8 times (6.7 × 10^5^/mm^3^; P≤0.01) the mean (3.7 × 10^5^/mm^3^) of the female control group. In contrast, the mean reticulocyte count of the female group (Figure 9) treated with 200 mg of AZT + 200 mg of rifampicin was approximately 86% (0.9 × 10^5^/mm^3^; P≤0.01) lower than the mean (3.7 × 10^5^/mm^3^) of the female control group. Female mice treated with 400 mg of AZT + 200 mg of rifampicin as well as 100, 200, or 400 mg of AZT + 400 mg of rifampicin died prior to day 92.

In general, treatment with combinations of AZT and rifampicin caused thrombocytosis in male and female mice except in severely anemic animals, probably due to bone marrow depression. On day 4, only slight elevations in platelet counts occurred. Although not consistently significant (P≤0.05), platelet counts of all male and female treatment groups receiving combination therapy were higher than the mean platelet counts of the respective control groups (Figures 10 and 11). The highest mean platelet count in males occurred in the group treated with 200 mg of AZT + 400 mg of rifampicin (Figure 10) and was approximately 1.2 times (1,519 × 10^3^/mm^3^) the mean (1,310 × 10^3^/mm^3^) of the male control group. For the females, the highest mean platelet count occurred in the group treated with 400 mg of AZT + 400 mg of rifampicin (Figure 11) and was approximately 1.2 times (1,318 × 10^3^/mm^3^; P≤0.01) the mean (1,124 × 10^3^/mm^3^) of the female control group.

On day 30, mean platelet counts of all male groups (Figure 10) treated with combinations of AZT and rifampicin were higher than the mean of the controls and the elevations were statistically significant in the higher dose combination groups with survivors. The peak mean platelet count occurred in the male group treated with 200 mg of AZT + 400 mg of rifampicin (Figure 10) and was approximately 1.7 times (2,359 × 10^3^/mm^3^; P≤0.01) the mean (1,427 × 10^3^/mm^3^) of the male control group. Male mice treated with 400 mg of AZT + 400 mg of rifampicin did not survive. For the female mice, the peak platelet count occurred in the group treated with 200 mg of AZT + 200 mg of rifampicin (Figure 11) and was approximately 1.8 times (2,036 × 10^3^/mm^3^; P≤0.01) the mean (1,129 × 10^3^/mm^3^) of the female control group. A distinct thrombocytopenia occurred in the female group treated with 400 mg of AZT + 400 mg of rifampicin (Figure 11). The mean platelet count of this group was approximately 73% (307 × 10^3^/mm^3^; P≤0.05) lower than the mean (1,129 × 10^3^/mm^3^) of the control. The marked thrombocytopenia corresponds with the severe anemia and generalized bone marrow depression observed in this group.

On day 60, thrombocytosis occurred in all surviving male groups (Figure 10) treated with combinations of AZT and rifampicin. The peak mean platelet value was observed in the male group treated with 400 mg of AZT + 200 mg of rifampicin (Figure 10) and was approximately 2.2 times (2,313 × 10^3^/mm^3^; P≤0.01) the mean (1,073 × 10^3^/mm^3^) of the male control group. Male mice treated with 200 or 400 mg of AZT + 400 mg of rifampicin did not survive to day 60. For the surviving female groups (Figure 11) on day 60, statistically significant (P≤0.05) elevations in platelet counts did not occur. Female mice treated with 400 mg of AZT + 200 mg of rifampicin as well as those treated with 100, 200, or 400 mg of AZT + 400 mg of rifampicin did not survive to day 60.

At the time of terminal sacrifice (days 92 to 95), prominent thrombocytosis occurred in male and female mice treated with combinations of AZT and rifampicin. The peak mean platelet count of the males occurred in the group treated with 400 mg of AZT + 200 mg of rifampicin (Figure 10) and was approximately 2.7 times (3,144 × 10^3^/mm^3^; P≤0.01) the mean (1,146 × 10^3^/mm^3^) of the control group. For the single surviving male mouse in the group treated with 200 mg of AZT + 400 mg of rifampicin (Figure 10), thrombocytopenia indicative of bone marrow toxicity occurred, and the platelet count was approximately 61% (445 × 10^3^/mm^3^) lower than the mean (1,146 × 10^3^/mm^3^) of the male control group. Male mice treated with 400 mg of AZT + 400 mg of rifampicin did not survive to day 92. For the female mice, the peak platelet value occurred in the group treated with 100 mg of AZT + 200 mg of rifampicin (Figure 11) and was approximately 2.3 times (2,209 × 10^3^/mm^3^; P≤0.01) the mean (975 × 10^3^/mm^3^) of the female control group. Female mice treated with 400 mg of AZT + 200 mg of rifampicin as well as those treated with 100, 200, or 400 mg of AZT + 400 mg of rifampicin did not survive to day 92.

Leukopenia, considered to be compatible with bone marrow toxicity, occurred on day 30 in female groups treated with combinations of AZT and rifampicin. The lowest WBC count occurred in the female group treated with 400 mg of AZT + 400 mg of rifampicin (Figure 15) and was approximately 80% (1.29 × 10^3^/mm^3^; P≤0.01) lower than the mean (6.47 × 10^3^/mm^3^) of the female control group. Evaluation of the corresponding differential data revealed statistically significant (P≤0.01 to 0.05) declines in both neutrophils and lymphocytes. Significant alterations in leukocyte counts (P≤0.05) did not occur in surviving male or female mice on day 60 or at terminal sacrifice. At the time of terminal sacrifice, although not statistically significant, lower WBC and differential counts were observed in the single surviving male mouse (Figure 14) treated with 200 mg of AZT + 400 mg of rifampicin as well as in the four surviving female mice (Figure 15) treated with 200 mg of AZT + 200 mg of rifampicin. These lower WBC counts are compatible with bone marrow depression.

In summary, both AZT and rifampicin produced a mild dose-related anemia when administered alone to male and female mice. The severity of the hematological alterations tended to be greater in females than in males. The anemia produced by AZT was accompanied by macrocytosis, whereas the anemia produced by rifampicin was accompanied by microcytosis. Male and female mice treated with combinations of AZT and rifampicin developed severe anemia, and the severity of the anemia was considered to be a contributing factor to the mortality that occurred in mice treated with the high dose combinations. The severe anemia and mortality were accompanied by bone marrow depression and hematopoietic cell proliferation in the spleen. Significant treatment-related alterations also occurred in reticulocyte counts. A prominent reticulocytopenia developed early (day 4) subsequent to the administration of AZT alone and also rifampicin alone. Combination therapy enhanced the severity of the reticulocytopenia. Reticulocyte counts in general tended to rebound by day 30; however, for those groups that died later in the study from severe anemia, reticulocyte counts decreased. Thrombocytosis tended to occur subsequent to treatment with AZT alone, whereas administration of rifampicin alone had a negligible effect on platelet counts. With the exception of mice treated with the high-dosage combinations, for which bone marrow toxicity was quite prominent, combinations of AZT and rifampicin tended to enhance the magnitude of the thrombocytosis.

### Clinical Chemistry

#### AZT Alone

Statistically or biologically significant alterations did not occur in any of the clinical chemistry parameters evaluated in male or female mice treated with 100, 200, or 400 mg of AZT alone. Clinical chemistry values are listed in Appendix A.

#### Rifampicin Alone

Administration of 100, 200, or 400 mg of rifampicin alone resulted in treatment-related elevations in alkaline phosphatase (ALP) activity in male and female mice (Appendix A). On day 30, respective mean ALP values in male mice (Figure 16) treated with 100, 200, or 400 mg of rifampicin were approximately 1.3 times (116 U/L; P≤0.01), 1.2 times (111 U/L; P≤0.05), and 2.0 times (178 U/L; P≤0.01) the mean ALP value (89 U/L) of the male control group. Respective mean ALP values on day 30 in female mice (Figure 17) treated with identical doses of rifampicin alone were approximately 1.1 times (163 U/L), 1.4 times (193 U/L; P≤0.01), and 1.4 times (200 U/L; P≤0.01) the mean (142 U/L) of the female control group. Similar treatment-related increases in ALP activity occurred on day 60. Respective mean ALP values on day 60 of male mice (Figure 16) treated with the above doses were approximately 1.3 times (122 U/L; P≤0.01), 1.9 times (170 U/L; P≤0.01), and 2.6 times (239 U/L; P≤0.01) the mean (91 U/L) of the male control group. Respective mean ALP values of female mice (Figure 17) treated with same doses were approximately 1.0 times (139 U/L), 1.2 times (166 U/L; P≤0.01), and 1.5 times (197 U/L; P≤0.01) the mean (135 U/L) of the control group. At the time of terminal sacrifice (days 92 to 95), similar increases in ALP activity occurred. Respective mean ALP values in male mice (Figure 16) treated with 100, 200, or 400 mg of rifampicin alone were approximately 1.7 times (135 U/L; P≤0.01), 2.4 times (190 U/L; P≤0.01), and 3.2 times (258 U/L; P≤0.01) the mean (80 U/L) of the male control group. Respective mean ALP values in female mice (Figure 17) treated with the above doses were approximately 1.2 times (136 U/L), 1.4 times (152 U/L; P≤0.01), and 1.6 times (182 U/L; P≤0.01) higher than the mean (112 U/L) of the female control group.

Treatment-related increases in alanine aminotransferase (ALT) activity occurred in male and female mice treated with 200 or 400 mg of rifampicin alone (Figures 18 and 19). On day 30, the mean ALT value of the female group treated with 400 mg of rifampicin alone (Figure 19) was approximately 3.2 times (82 U/L; P≤0.01) the mean (26 U/L) of the female control group. Significant (P≤0.05) elevations in ALT values did not occur in the male groups on day 30. On day 60, the mean ALT value in the male group (Figure 18) treated with 400 mg of rifampicin alone was approximately 7.4 times (208 U/L; P≤0.01) the mean (28 U/L) of the male control group. Significant (P≤0.05) increases in ALT values did not occur in the female mice on day 60. At the time of terminal sacrifice (days 92 to 95), respective mean ALT values in male mice treated with 200 or 400 mg of rifampicin alone were approximately 3.1 times (69 U/L; P≤0.01) and 7.0 times (153 U/L) the mean of the male control (22 U/L) group. The mean ALT value in female mice (Figure 19) treated with 400 mg of rifampicin was approximately 4.3 times (85 U/L; P≤0.01) the mean (20 U/L) of the female control group.

FIGURE 16 Mean Alkaline Phosphatase Values for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection; + = last animal in this group died prior to collection of clinical chemistry sample.)

FIGURE 17 Mean Alkaline Phosphatase Values for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

FIGURE 18 Mean Alanine Aminotransferase Values for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection; + = last animal in this group died prior to collection of clinical chemistry sample.)

FIGURE 19 Mean Alanine Aminotransferase Values for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

(* All mice in this group died prior to blood collection)

Mild compound-related increases in aspartate aminotransferase (AST) activity occurred in male and female mice treated with 400 mg of rifampicin alone. Statistically significant (P≤0.05) elevations in AST activity did not occur in male or female mice on day 4 or in male mice on day 30. On day 30 for the female group treated with 400 mg of rifampicin alone, the mean AST value was approximately 1.5 times (103 U/L; P≤0.05) the mean (71 U/L) of the female control group. On day 60, the mean AST value in the male group treated with 400 mg of rifampicin alone was approximately 2.5 times (157 U/L; P≤0.01) the mean (63 U/L) of the male control. Elevations in AST values did not occur in the female groups on day 60. At the time of terminal sacrifice (days 92 to 95), the mean AST value in male mice treated with 400 mg of rifampicin alone was approximately 2.2 times (148 U/L; P≤0.01) the mean of the male control group. Although not statistically significant (P≤0.05), female mice treated with 400 mg had a mean AST value approximately 1.4 times (112 U/L) the mean (80 U/L) of the female control group.

With the exception of female mice in the 400 mg group, insufficient serum samples prevented adequate statistical comparisons for sorbitol dehydrogenase (SDH) activity and bile acid levels. The mean SDH value on day 60 in female mice treated with 400 mg of rifampicin alone was approximately 1.5 times (44 U/L; P≤0.05) the mean (29 U/L) in the female control group. Although not statistically significant (P≤0.05), the mean bile acid level in the same treatment group was approximately 2.1 times (73 μmol/L) the mean bile acid level (34 μmol) of two samples in the female control group (Appendix A).

Dose and duration of treatment-related increases in ALP, ALT, and AST activities indicate that rifampicin caused hepatotoxicity.

#### AZT and Rifampicin Combinations

Increased ALP activity was observed in male and female mice treated with combinations of AZT and rifampicin in a manner similar to mice treated with rifampicin alone (Appendix A). On day 4, ALP values in male and female mice (Figures 16 and 17) treated with AZT and rifampicin were within a normal range. On day 30, ALP values in all male groups (Figure 16) treated with AZT and rifampicin were higher than the mean ALP value of the control group. The peak ALP value occurred in the group treated with 100 mg of AZT + 400 mg of rifampicin and was approximately 1.7 times (155 U/L; P≤0.01) the mean (89 U/L) of the male control group. Only slight increases were observed in female groups on day 30. The highest value in female mice (Figure 17) was observed in the group treated with 100 mg of AZT + 400 mg of rifampicin and was approximately 1.2 times (173 UIL; P≤0.05) the mean (142 U/L) of the female control group. On day 60, significant elevations (P≤0.01) in ALP levels occurred in all surviving male groups (Figure 16) treated with combination therapy. The peak ALP value occurred in the male group treated with 100 mg of AZT + 400 mg of rifampicin and was approximately 2.8 times (252 U/L; P≤0.01) the mean (91 UIL) of the male control group. Male mice treated with 200 or 400 mg of AZT + 400 mg of rifampicin did not survive. Statistically significant (P≤0.05) elevations in ALP activity did not occur on day 60 in female mice treated with combinations of AZT and rifampicin. Female groups treated with 400 mg of AZT + 200 mg of rifampicin and 100, 200, or 400 mg of AZT + 400 mg of rifampicin did not survive. At the time of terminal sacrifice (days 92 to 95), significant elevations (P≤0.01) in ALP activity occurred in all surviving male groups (Figure 16). The peak value occurred in the male group treated with 100 mg of AZT + 400 mg of rifampicin and was approximately 2.6 times (208 U/L; P≤0.01) the mean in the male control group (80 UIL). Male groups treated with 200 or 400 mg of AZT + 400 mg of rifampicin did not survive until terminal sacrifice. For the female mice at terminal sacrifice (days 92 to 95), the peak ALP value occurred in the group treated with 200 mg of AZT + 200 mg of rifampicin (Figure 17) and was approximately 1.6 times (183 U/L; P≤0.01) the mean (112 U/L) in the female control group. Female groups treated with 400 mg of AZT + 200 mg of rifampicin and 100, 200, or 400 mg of AZT + 400 mg of rifampicin did not survive to day 92.

Increased ALT values indicative of liver toxicity also occurred in mice treated with AZT and rifampicin combinations, and the most prominent increases were observed in groups that received 400 mg of rifampicin in combination with AZT (Appendix A). On day 4, elevated ALT values occurred in female mice treated with AZT and rifampicin combinations. The peak ALT value occurred in the female group treated with 400 mg of AZT + 400 mg of rifampicin (Figure 19) and was approximately 2.1 times (63 U!L; P≤0.01) the mean (30 U/L) in the female control group. Significant elevations (P≤0.05) in ALT values did not occur on day 4 in male mice. On day 30, the ALT value in the female group treated with 100 mg of AZT + 400 mg of rifampicin (Figure 19) was approximately 2.3 times (59 U/L; P≤0.05) the mean (26 U/L) of the female control group. Significant increases (P≤0.05) in ALT values did not occur on day 30 in male mice. On day 60, elevated ALT values occurred in male mice that received 200 or 400 mg of rifampicin in combination with AZT. The peak ALT value occurred in the male group treated with 100 mg of AZT + 400 mg of rifampicin (Figure 18) and was approximately 5.1 times (143 U/L; P≤0.01) the mean (28 U/L) of the male control group. Significant increases (P≤0.05) did not occur on day 60 in female mice receiving combination therapy. At the time of terminal sacrifice (days 92 to 95), elevated ALT activity was observed only in the male group treated with 100 mg of AZT + 400 mg of rifampicin (Figure 18) and it was approximately 4.4 times (96 UIL; P≤0.01) the mean (22 UIL) of the male control group. Significant elevations (P≤0.05) in ALT values did not occur in female groups receiving combination therapy. Statistically significant (P≤0.05) increases in AST values did not occur in male or female mice treated with combinations of AZT and rifampicin (Appendix A). Although not statistically significant, elevated AST values indicative of liver toxicity was observed in one female group treated with 200 mg of AZT + 200 mg of rifampicin, with a mean AST value of approximately 1.8 times (143 U/L) the mean (80 UIL) of the female control group.

Insufficient serum samples prevented adequate statistical comparisons for SDH activity and bile acid levels in mice treated with combination therapy. Bile acid elevations appeared to occur in at least two of the combination dose groups on day 30. The single serum sample obtained on day 30 from the male group treated with 100 mg of AZT + 400 mg of rifampicin had a bile acid value of 144 μmol/L. Three female mice treated with 400 mg of AZT + 200 mg of rifampicin had a mean bile acid value of 137 μmol/L (Appendix A).

In summary, treatment with AZT alone did not result in any alterations in clinical chemistry parameters. Treatment with rifampicin alone resulted in dose-related increases in serum enzyme (ALP, ALT, and AST) activity, indicative of hepatotoxicity. The elevated serum enzymes corresponded well with increased liver weights and histopathological evidence of hepatotoxicity in the form of increased cytoplasmic vacuolization of hepatocytes. Treatment with combinations of AZT and rifampicin did not appear to exacerbate hepatotoxicity as serum enzyme levels in general were similar to those in mice treated with rifampicin alone.

## Necropsy Observations

Significant treatment-related lesions found at necropsy consisted of enlarged and/or pale livers and pale carcasses. The pale and enlarged livers occurred primarily in male and female groups treated with rifampicin alone or combinations of AZT and rifampicin. The incidence of enlarged pale livers corresponded in general with increased liver weights (Table 3), elevated serum enzymes (Tables A3 and A4), and cytoplasmic vacuolization of hepatocytes (Tables 4 and 5) suggestive of hepatotoxicity. In general, the incidence of pale carcass corresponded with the increased severity of anemia evident in the hematology parameters of groups treated with higher combination doses of AZT and rifampicin.

TABLE 4 Incidence and Mean Severity of Cytoplasmic Vacuolization of Hepatocytes of the Liver in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Male | | Female
Dose | Group Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 | 10/10 | 1 6 | 8/10 | 1 0
100 + 0 | 10/10 | 1 7 | 10/10 | 1 0
200 + 0 | 10/10 | 1 8 | 10/10 | 1 3
400 + 0 | 10/10 | 1 5 | 9/10 | 1 1
0 + 100 | 10/10 | 3 0 | 10/10 | 1 3
100 + 100 | 10/10 | 3 1 | 9/9 | 1 7
200 + 100 | 10/10 | 3 1 | 10/10 | 1 5
400 + 100 | 10/10 | 3 5 | 10/10 | 1 6
0 + 200 | 10/10 | 4 0 | 10/10 | 1 5
100 + 200 | 9/9 | 3 7 | 10/10 | 2 4
200 + 200 | 10/10 | 3 0 | 9/10 | 2 8
400 + 200 | 10/10 | 2 9 | 10/10 | 2 4
0 + 400 | 10/10 | 3 6 | 10/10 | 2 9
100 + 400 | 10/10 | 3 2 | 10/10 | 3 1
200 + 400 | 10/10 | 3 0 | 10/10 | 2 9
400 + 400 | 10/10 | 3 1 | 10/10 | 2 7

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean severity is for mice with lesions and is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

TABLE 5 Statistical Analysis of Mean Severity of Cytoplasmic Vacuolization of Hepatocytes of the Liver in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
Dose^a^ | Male^c^ | Female^c^
0 + 0 | 1 60 ± 0 22 | 0 90 ± 0 11^d^
100 + 0 | 1 70 ± 0 21 | 1 00 ± 0 00
200 + 0 | 1 80 ± 0 13 | 1 30 ± 0 15^*^
400 + 0 | 1 50 ± 0 17 | 1 00 ± 0 15
0 + 100 | 3 00 ± 0 00^**^ | 1 30 ± 0 15^*^
100 + 100 | 3 10 ± 0 10^**^ | 1 70 ± 0 17^**^
200 + 100 | 3 10 ± 0 10^**^ | 1 50 ± 0 17^**^
400 + 100 | 3 50 ± 0 17^**^ | 1 60 ± 0 27^*^
0 + 200 | 4 00 ± 0 00^**^ | 1 50 ± 0 17^**^
100 + 200 | 3 70 ± 0 17^**^,^d^ | 2 40 ± 0 22^**^
200 + 200 | 3 00 ± 0 00^**^ | 2 50 ± 0 34^**^
400 + 200 | 2 90 ± 0 10^**^ | 2 40 ± 0 16^**^
0 + 400 | 3 60 ± 0 16^**^ | 2 90 ± 0 10^**^
100 + 400 | 3 20 ± 0 13^**^ | 3 10 ± 0 10^**^
200 + 400 | 3 00 ± 0 15^**^ | 2 90 ± 0 10^**^
400 + 400 | 3 10 ± 0 18^**^ | 2 70 ± 0 15^**^

* Significantly different from the control group (P≤0.05) by Dunnett’s test

** P≤0 01

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group, mean severity is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=9

## Histopathologic Observations

Treatment-related lesions were observed in bone marrow, liver, spleen, thymus, and testis. No treatment-related lesions were observed in the other organs examined. Photomicrographs of treatment-related lesions are illustrated in Plates 1 through 10 and summarized in Table 6.

TABLE 6 List of Photomicrographs (Plates) of Compound-Related Lesions in Male B6C3F_1_ Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Tissue | Magnification | Plate Number | Treatment-Related Lesions
0 + 0 | Bone Marrow | 450× | 1 | None
200 + 400 | Bone Marrow | 450× | 2 | Cellular depletion (marked)
0 + 0 | Liver | 450× | 3 | None
0 + 400 | Liver | 450× | 4 | Cytoplasmic vacuolization (marked)
0 + 0 | Spleen | 400× | 5 | None
200 + 400 | Spleen | 400× | 6 | Cellular depletion (moderate)
0 + 0 | Thymus | 400× | 7 | None
200 + 400 | Thymus | 400× | 8 | Atrophy (marked)
0 + 0 | Testis | 450× | 9 | None
200 + 400 | Testis | 450× | 10 | Degeneration of germinal epithelium (mild)

a AZT + rifampicin (mg/kg per day)

### Bone Marrow Lesions

Cellular depletion of the bone marrow occurred in all groups treated with AZT alone (Table 7) and involved primarily cells of the erythrocytic series. Alterations in the bone marrow seldom occurred in mice treated with rifampicin alone. Criteria for severity grades of cellular depletion of the bone marrow were as follow:

- Minimal - approximately 5% or less of the hematopoietic cells of the bone marrow
- Mild - approximately 6% to 20% of the hematopoietic cells of the bone marrow
- Moderate - approximately 21% to 50% of the hematopoietic cells of the bone marrow
- Marked - more then 50% of the hematopoietic cells of the bone marrow

TABLE 7 Incidence and Mean Severity of Cellular Depletion of the Bone Marrow in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Male | | Female
Dose | Group Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 | 0/10 | — | 0/10 | —
100 + 0 | 2/10 | 1 0 | 5/10 | 1 0
200 + 0 | 6/10 | 1 0 | 8/10 | 1 0
400 + 0 | 6/10 | 1 0 | 7/10 | 1 3
0 + 100 | 0/10 | — | 0/10 | —
100 + 100 | 0/10 | — | 6/9 | 1 0
200 + 100 | 7/10 | 1 0 | 10/10 | 1 1
400 + 100 | 4/10 | 1 0 | 7/10 | 2 0
0 + 200 | 0/10 | — | 0/10 | —
100 + 200 | 9/9 | 1 4 | 10/10 | 1 9
200 + 200 | 6/10 | 1 2 | 10/10 | 2 9
400 + 200 | 10/10 | 3 0 | 10/10 | 4 0
0 + 400 | 1/10 | 1 0 | 0/10 | —
100 + 400 | 10/10 | 3 0 | 10/10 | 3 6
200 + 400 | 10/10 | 3 7 | 10/10 | 3 7
400 + 400 | 10/10 | 3 7 | 10/10 | 3 9

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean severity is for mice with lesions and is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

The incidence of cellular depletion of bone marrow increased in male and female mice treated with combinations of AZT and rifampicin. Significant increases (P≤0.05 to P≤0.01) in the severity of this lesion occurred in the groups treated with combination therapy, and the degree of severity increased (Table 8) as dose levels of AZT and rifampicin increased. The increased severity of bone marrow depletion corresponded in general with decreased erythrocyte counts in blood.

Hematopoietic cell proliferation in the red pulp of the spleen was a treatment-related lesion, and it was observed in male and female mice. Criteria for severity grades of hematopoietic cell proliferation were as follows:

- Minimal - the number of hematopoietic cells in the red pulp is estimated to be increased, but these cells do not occupy more than 15% of the red pulp
- Mild - hematopoietic cells are estimated to occupy approximately 16% to 50% of the splenic red pulp

PLATE 1 Bone marrow of a vehicle control male B6C3F_1_ mouse showing no lesions. H&E;450×

PLATE 2 Bone marrow of a male B6C3F_1_ mouse given 200 mg AZT + 400 mg rifampicin per kg body weight per day by gavage for 13 weeks showing marked cellular depletion. H&E; 450×

PLATE 3 Liver of a vehicle control male B6C3F_1_ mouse showing no lesions. H&E; 450×

PLATE 4 Liver of a male B6C3F_1_ mouse given 400 mg rifampicin per kg body weight per day by gavage for 13 weeks showing marked cytoplasmic vacuolization. H&E; 450×

PLATE 5 Spleen of a vehicle control male B6C3F_1_ mouse showing no lesions. H&E. 400×

PLATE 6 Spleen of a male B6C3F_1_ mouse given 200 mg AZT + 400 mg rifampicin per kg body weight per day for 13 weeks showing moderate cellular depletion. H&E; 400×

PLATE 7 Thymus of a vehicle control male B6C3F_1_ mouse showing no lesions. H&E; 400×

PLATE 8 Thymus of a male B6C3F_1_ mouse given 200 mg AZT + 400 mg rifampicin per kg body weight per day for 13 weeks showing marked atrophy. H&E; 400×

PLATE 9 Testis of a vehicle control male B6C3F_1_ mouse showing no lesions. H&E; 450×

PLATE 10 Testis of a male B6C3F_1_ mouse given 200 mg AZT + 400 mg rifampicin per kg body weight per day for 13 weeks showing mild degeneration of germinal epithelium. H&E; 450×

TABLE 8 Statistical Analysis of Mean Severity of Cellular Depletion of the Bone Marrow in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
Dose^a^ | Male^c^ | Female^c^
0 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00^d^
100 + 0 | 0 20 ± 0 13 | 0 50 ± 0 17^*^
200 + 0 | 0 60 ± 0 16^**^ | 0 80 ± 0 13^**^
400 + 0 | 0 50 ± 0 17^**^ | 0 90 ± 0 23^**^
0 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 100 | 0 00 ± 0 00 | 0 67 ± 0 17^**^
200 + 100 | 0 70 ± 0 15^**^ | 1 10 ± 0 10^**^
400 + 100 | 0 40 ± 0 16^*^ | 1 40 ± 0 48^*^
0 + 200 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 200 | 1 44 ± 0 18^**^,^d^ | 1 90 ± 0 31^**^
200 + 200 | 0 70 ± 0 21^**^ | 2 90 ± 0 31^**^
400 + 200 | 3 00 ± 0 45^**^ | 4 00 ± 0 00^**^
0 + 400 | 0 10 ± 0 10 | 0 00 ± 0 00
100 + 400 | 3 00 ± 0 39^**^ | 3 60 ± 0 16^**^
200 + 400 | 3 70 ± 0 15^**^ | 3 70 ± 0 15^**^
400 + 400 | 3 70 ± 0 15^**^ | 3 90 ± 0 10^**^

* Significantly different from the control group (P≤0 05) by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group, mean seventy is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=9

### Spleen Lesions

Both AZT and rifampicin given alone resulted in a dose-related increase in the incidence (Table 9) and severity (Table 10) of splenic hematopoiesis in male and female mice. Significant increases in severity (P≤0.05 to P≤0.01) occurred in male mice treated With 100, 200, or 400 mg of AZT in combination with 100 mg of rifampicin. Male mice treated with higher combinations of AZT and rifampicin did not have increased hematopoiesis in the red pulp, as many of these mice died early from severe anemia. For the female mice, significant increases (P≤0.01) in severity occurred in groups treated with 100 or 200 mg of AZT in combination with 100 mg of rifampicin or 100 mg of AZT + 200 mg of rifampicin. Female groups treated with higher combinations of AZT and rifampicin developed severe anemia accompanied by increased mortality rates. Lower incidence and severity of hematopoiesis in the red pulp occurred in these groups with severe anemia and increased mortality.

TABLE 9 Incidence and Mean Severity of Hematopoietic Cell Proliferation of the Spleen in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Male | | Female
Dose | Gronp Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 | 2/10 | 1 5 | 5/10 | 1 0
100 + 0 | 5/10 | 1 0 | 8/10 | 1 0
200 + 0 | 7/10 | 1 3 | 9/10 | 1 7
400 + 0 | 7/10 | 1 4 | 9/10 | 1 7
0 + 100 | 9/10 | 1 0 | 10/10 | 2 0
100 + 100 | 8/10 | 1 4 | 9/9 | 2 0
200 + 100 | 10/10 | 1 6 | 10/10 | 2 0
400 + 100 | 10/10 | 1 8 | 6/10 | 2 0
0 + 200 | 6/10 | 1 2 | 10/10 | 1 9
100 + 200 | 9/9 | 1 8 | 8/10 | 2 0
200 + 200 | 9/10 | 1 8 | 3/10 | 1 0
400 + 200 | 2/10 | 1 0 | 0/10 | —
0 + 400 | 10/10 | 1 6 | 10/10 | 2 0
100 + 400 | 2/10 | 1 0 | 0/10 | —
200 + 400 | 0/10 | — | 0/10 | —
400 + 400 | 0/10 | — | 0/10 | —

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean seventy is for mice with lesions and is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

TABLE 10 Statistical Analysis of Mean Severity of Hematopoietic Cell Proliferation of the Spleen in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
Dose^a^ | Male^c^ | Female^c^
0 + 0 | 0 30 ± 0 21 | 0 56 ± 0 18^d^
100 + 0 | 0 50 ± 0 17 | 0 80 ± 0 13
200 + 0 | 0 90 ± 0 23 | 1 50 ± 0 22^**^
400 + 0 | 1 00 ± 0 26 | 1 50 ± 0 22^**^
0 + 100 | 0 90 ± 0 10^*^ | 2 00 ± 0 00^**^
100 + 100 | 1 10 ± 0 23^*^ | 2 00 ± 0 00^**^,^d^
200 + 100 | 1 60 ± 0 16^**^ | 2 00 ± 0 00^**^
400 + 100 | 1 80 ± 0 13^**^ | 1 20 ± 0 33
0 + 200 | 0 70 ± 0 21 | 1 90 ± 0 10^**^
100 + 200 | 1 78 ± 0 15^**^,^d^ | 1 60 ± 0 27^**^
200 + 200 | 1 60 ± 0 22^**^ | 0 30 ± 0 15
400 + 200 | 0 20 ± 0 13 | 0 00 ± 0 00^**^
0 + 400 | 1 60 ± 0 16^**^ | 2 00 ± 0 00^**^
100 + 400 | 0 20 ± 0 13 | 0 00 ± 0 00^**^
200 + 400 | 0 00 ± 0 00 | 0 00 ± 0 00^**^
400 + 400 | 0 00 ± 0 00 | 0 00 ± 0 00^**^

* Significantly different from the control group (P≤0.05) by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group, mean severity is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=9

Cellular depletion of the spleen occurred only in male and female mice treated with the higher combinations of AZT and rifampicin (Table 11). The depletion of cells occurred in both the white and red pulp, and the criteria for severity grades were as follows:

- Minimal - estimated depletion of 1% to 20% of the cells of the spleen
- Mild - estimated depletion of 21% to 40% of the cells of the spleen
- Moderate - estimated depletion of 41% to 60% of the cells of the spleen
- Marked - estimated depletion of more than 60% of the cells of the spleen

In male mice, significant increases (P≤−0.01) in the severity of cellular depletion (Table 12) occurred in the group treated with 400 mg of AZT + 200 mg of rifampicin and in the groups treated with 100, 200, or 400 mg of AZT in combination with 400 mg of rifampicin. For the female groups, significant increases (P≤0.01) in severity of cellular depletion of the spleen occurred in the groups treated with 200 or 400 mg of AZT + 200 mg rifampicin as well as in the groups treated with 100, 200, or 400 mg of AZT + 400 mg of rifampicin. In general, cellular depletion of the spleen was observed in male and female mice with severe anemia and high mortality due to severe hematological toxicity.

### Liver Lesions

An increase in the severity (P≤0.05 to P≤0.01) of cytoplasmic vacuolization of hepatocytes occurred in male and female groups treated with rifampicin alone or in combination with AZT (Tables 4 and 5). Small cytoplasmic vacuolizations, believed to be the result of glycogen deposition, are a normal finding in well-nourished mice. With increasing doses of rifampicin, there was a corresponding increase in round cytoplasmic vacuoles typical of fat vacuoles, and the vacuolization was most prominent in the centrilobular areas of the liver. Criteria for the severity grades of cytoplasmic vacuolization were as follows:

- Minimal - approximately 1% to 15% of hepatocytes containing round cytoplasmic vacuoles
- Mild - approximately 16% to 35% of hepatocytes containing round cytoplasmic vacuoles
- Moderate - approximately 36% to 60% of hepatocytes containing round cytoplasmic vacuoles
- Marked - more than 60% of hepatocytes containing round cytoplasmic vacuoles

In general, cytoplasmic vacuolization of hepatocytes was more prominent in male mice than in females. Hepatocyte cytoplasmic vacuolization in the liver corresponded with increased liver-to-body-weight ratios and increases in serum enzymes typical of hepatotoxicity.

TABLE 11 Incidence and Mean Severity of Cellular Depletion of the Spleen in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Male | | Female
Dose | Group Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 | 0/10 | — | 0/10 | —
100 + 0 | 0/10 | — | 0/10 | —
200 + 0 | 0/10 | — | 0/10 | —
400 + 0 | 0/10 | — | 0/10 | —
0 + 100 | 0/10 | — | 0/10 | —
100 + 100 | 0/10 | — | 0/9 | —
200 + 100 | 0/10 | — | 0/10 | —
400 + 100 | 0/10 | — | 2/10 | 1 5
0 + 200 | 0/10 | — | 0/10 | —
100 + 200 | 0/9 | — | 1/10 | 2 0
200 + 200 | 0/10 | — | 8/10 | 2 5
400 + 200 | 7/10 | 3 0 | 10/10 | 3 1
0 + 400 | 0/10 | — | 0/10 | —
100 + 400 | 8/10 | 2 6 | 10/10 | 2 9
200 + 400 | 10/10 | 2 8 | 9/10 | 2 8
400 + 400 | 9/10 | 2 6 | 10/10 | 2 7

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean severity is for mice with lesions and is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

TABLE 12 Statistical Analysis of Mean Severity of Cellular Depletion of the Spleen in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
Dose^a^ | Male^c^ | Female^c^
0 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00^d^
100 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00
200 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00
400 + 0 | 0 00 + 0 00 | 0 00 ± 0 00
0 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
200 + 100 | 0 00 + 0 00 | 0 00 ± 0 00
400 + 100 | 0 00 ± 0 00 | 0 30 ± 0 21
0 + 200 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 200 | 0 00 ± 0 00^d^ | 0 20 ± 0 20
200 + 200 | 0 00 ± 0 00 | 2 00 ± 0 42^**^
400 + 200 | 2 10 ± 0 46^**^ | 3 10 ± 0 10^**^
0 + 400 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 400 | 2 10 ± 0 41^**^ | 2 90 ± 0 28^**^
200 + 400 | 2 80 ± 0 13^**^ | 2 50 ± 0 34^**^
400 + 400 | 2 30 ± 0 30^**^ | 2 70 ± 0 21^**^

** Significantly different from the control group (P≤0.01) by Dunnett’s test

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group, mean severity is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=9

### Thymus Lesions

An increase in the incidence and the degree of severity (P≤0.05 to P≤0.01) of atrophy of the thymus was observed in male and female groups treated with the higher combinations of AZT and rifampicin (Tables 13 and 14). Significant alterations in the thymus did not occur in groups treated with AZT or rifampicin alone. Thymic atrophy was characterized by a reduction in the size of the thymus alone with a reduction in the number of lymphocytes. Criteria for severity grades of thymic atrophy were as follows:

- Minimal - reduction of 10% or less lymphocytes in the cortex
- Mild - reduction of approximately 11% to 25% of lymphocytes in the cortex
- Moderate - reduction of approximately 26% to 50% of lymphocytes in the cortex
- Marked - reduction of approximately 51% or greater lymphocytes in the cortex

Atrophy of the thymus was more prominent in female groups treated with drug combinations than in males and, in general, corresponded with treatment-related decreases in thymus weights. Decreases in thymus weights and severity of thymic atrophy appear to be due to dose-related loss or decrease in body weights and severity of anemia. Stress of anemia appears to have contributed to thymic atrophy.

### Testis Lesions

Testicular degeneration was observed in the group treated with 400 mg of AZT in combination with 200 mg of rifampicin and in the groups treated with 100, 200, or 400 mg of AZT in combination with 400 mg of rifampicin (Tables 15 and 16). Microscopically, testicular degeneration was characterized by disruption of the orderly arrangement of germinal cells in seminiferous tubules with decreased numbers and necrosis of germinal cells, and the formation of multinucleated giant cells. Criteria for severity grades were as follows:

- Minimal - degeneration in approximately 5% or less of seminiferous tubules
- Mild - degeneration in approximately 6% to 40% of seminiferous tubules
- Moderate - degeneration in approximately 41% to 80% of seminiferous tubules

The degree of severity (P≤0.01) of testicular degeneration was similar in all of the affected groups. In general, the testicular degeneration was accompanied by lower testis weights and sperm motility.

TABLE 13 Incidence and Mean Severity of Thymic Atrophy in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Male | | Female
Dose | Group Incidence | Mean Severity | Group Incidence | Mean Severity
0 + 0 | 0/10 | — | 0/10 | —
100 + 0 | 0/10 | — | 0/10 | —
200 + 0 | 0/10 | — | 0/10 | —
400 + 0 | 1/9 | 1 0 | 1/10 | 1 0
0 + 100 | 0/10 | — | 0/10 | —
100 + 100 | 0/10 | — | 0/9 | —
200 + 100 | 0/10 | — | 0/10 | —
400 + 100 | 0/10 | — | 4/10 | 3 3
0 + 200 | 0/10 | — | 0/10 | —
100 + 200 | 0/9 | — | 2/9 | 2 0
200 + 200 | 0/10 | — | 9/9 | 3 1
400 + 200 | 7/10 | 3 4 | 10/10 | 3 6
0 + 400 | 0/10 | — | 0/10 | —
100 + 400 | 7/8 | 3 3 | 8/8 | 3 5
200 + 400 | 9/9 | 3 3 | 8/8 | 3 3
400 + 400 | 5/5 | 3 6 | 8/8 | 3 5

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean severity is for mice with lesions and is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

TABLE 14 Statistical Analysis of Mean Severity of Thymic Atrophy in Male and Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
Dose^a^ | Male^c^ | Female^c^
0 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00^d^
100 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00
200 + 0 | 0 00 ± 0 00 | 0 00 ± 0 00
400 + 0 | 0 10 ± 0 10 | 0 10 ± 0 10
0 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
200 + 100 | 0 00 ± 0 00 | 0 00 ± 0 00
400 + 100 | 0 00 ± 0 00 | 1 30 ± 0 54^*^
0 + 200 | 0 00 ± 0 00 | 0 00 ± 0 00
100 + 200 | 0 00 ± 0 00^d^ | 0 40 ± 0 31
200 + 200 | 0 00 ± 0 00 | 2 80 ± 0 36^**^
400 + 200 | 2 40 ± 0 54^**^ | 3 60 ± 0 16^**^
0 + 400 | 0 00 ± 0 0 | 0 00 ± 0 00
100 + 400 | 2 30 + 0 52^**^ | 2 80 ± 0 49^**^
200 + 400 | 3 00 + 0 37^**^ | 2 60 ± 0 45^**^
400 + 400 | 1 80 ± 0 31^**^ | 2 80 ± 0 49^**^

* Significantly different from the control group (P≤0.05) by Dunnett’s test

** P<0 01

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Data are presented as mean ± standard error for all animals in the dose group, mean severity is based on the numeric scale of 1=minimal, 2=mild, 3=moderate, 4=marked

c n=10

d n=9

TABLE 15 Incidence and Mean Severity of Testicular Degeneration in Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | Group Incidence | Mean Severity
0 + 0 | 0/10 | —
100 + 0 | 0/10 | —
200 + 0 | 0/10 | —
400 + 0 | 0/10 | —
0 + 100 | 0/10 | —
100 + 100 | 0/10 | —
200 + 100 | 0/10 | —
400 + 100 | 0/10 | —
0 + 200 | 0/10 | —
100 + 200 | 0/9 | —
200 + 200 | 0/10 | —
400 + 200 | 7/10 | 1 9
0 + 400 | 0/8 | —
100 + 400 | 7/9 | 2 0
200 + 400 | 8/10 | 1 8
400 + 400 | 8/10 | 1 9

a Daily gavage doses of AZT + rifampicin (mg/kg per day) Mean severity is for male mice with lesions and is based on the numeric scale of 1=minimal, 2=mild

TABLE 16 Statistical Analysis of Mean Severity of Testicular Degeneration in Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations

Dose^a^ | Mean Severity^b^
0 + 0 | 0 00 ± 0 00
100 + 0 | 0 00 ± 0 00
200 + 0 | 0 00 ± 0 00
400 + 0 | 0 10 ± 0 10
0 + 100 | 0 00 ± 0 00
100 + 100 | 0 00 ± 0 00
200 + 100 | 0 00 ± 0 00
400 + 100 | 0 00 ± 0 00
0 + 200 | 0 00 ± 0 00
100 + 200 | 0 00 ± 0 00^c^
200 + 200 | 0 00 ± 0 00
400 + 200 | 1 30 ± 0 33^**^
0 + 400 | 0 00 ± 0 00
100 + 400 | 1 40 ± 0 31^**^
200 + 400 | 1 40 ± 0 31^**^
400 + 400 | 1 50 ± 0 31^**^

** Significantly different from the control group (P≤0.01) by Dunnett’s test

a Daily gavage doses of AZT + rifampicin (mg/kg per day), n=10

b Data are presented as mean ± standard error for all animals in the dose group, mean severity is based on the numeric scale of 1=minimal, 2=mild

c n=9

## Sperm Morphology and Motility and Vaginal Cytology

For left epididymal weights, testicular weights, and epididymal sperm motility in surviving animals (70% to 100% mortality in groups treated with 400 mg of rifampicin + all doses of AZT or with 400 mg of AZT + 200 mg of rifampicin), the dose response relationship of AZT differed across doses of rifampicin (Table 17). The values, in general, decreased with increasing doses of rifampicin. For left caudal weights, epididymal sperm count per gram of caudal tissue, total spermatid heads per testis, and total spermatid heads per gram of testis, there were no significant AZT or rifampicin effects and no interaction effect.

TABLE 17 Summary of Significant Reproductive Tissue Parameters in Male Mice Treated with AZT and Rifampicin Combinations

Dose^a^ | Left Epididymal Weight^b^ | Left Testicular Weight^b^ | Epididymal Sperm Motility^b^
0 + 0 | 0 043 ± 0 001(10) | 0 118 ± 0 002(10) | 86 25 ± 0 82(10)
100 + 0 | 0 043 ± 0 002(10) | 0 119 ± 0 004(10) | 84 69 ± 0 73(10)
200 + 0 | 0 044 ± 0 001(10) | 0 113 ± 0 002(10) | 85 01 ± 0 79(10)
400 + 0 | 0 043 ± 0 001(10) | 0 109 ± 0 003(10) | 81 45 ± 1 68(10)
0 + 100 | 0 043 ± 0 001(10) | 0 112 ± 0 002(10) | 83 64 ± 1 17(9)
100 + 100 | 0 043 ± 0 001(10) | 0 109 ± 0 001(10) | 84 22 ± 1 05(10)
200 + 100 | 0 044 ± 0 001(10) | 0 109 ± 0 003(10) | 77 95 ± 4 18(10)
400 + 100 | 0 043 ± 0 001(10) | 0 101 ± 0 003(10) | 80 89 ± 1 64(9)
0 + 200 | 0 043 ± 0 001(10) | 0 113 ± 0 003(10) | 85 06 ± 0 70(9)
100 + 200 | 0 043 ± 0 001(9) | 0 111 ± 0 002(9) | 80 65 ± 2 01(8)
200 + 200 | 0 041 ± 0 001(9) | 0 101 ± 0 003(9) | 83 38 ± 1 41(8)
400 + 200 | 0 042 ± 0 001(3) | 0 095 ± 0 004(3) | 55 10 ± 22 72(3)
0 + 400 | 0 041 ± 0 003(10) | 0 107 ± 0 004(10) | 78 90 ± 3 69(10)
100 + 400 | 0 036 ± 0 002(2) | 0 092 ± 0 005(2) | 39 05 ± 22 45(2)
200 + 400 | 0 022 ± (1) | 0 072 ± (1) | 0 00 ± (1)
400 + 400^c^ | — | — | —

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Results of a two-way analysis of variance indicate that the dose response relationship of AZT differs across doses of rifampicin, data are presented as mean ± standard error (number of animals providing data), left epididymal weight and left testicular weight expressed in grams, epididymal sperm motility expressed as percent (%)

c Data were not available due to 100% mortality in this group

The average estrous cycle length was not altered by AZT alone, rifampicin alone, or combinations of AZT and rifampicin. Results of a two-way analysis of variance indicated a significant interaction effect (P≤0.05) in the duration of estrus, metestrus, and diestrus (Table 18). This analysis indicated that the dose response relationship of AZT differed across doses of rifampicin. There was no significant change in the duration of proestrus. However, the reason for changes in the other phases of the estrous cycle in groups treated with the combinations of AZT and rifampicin is not known.

TABLE 18 Estrous Cycle Phases in Female Mice Treated with AZT and Rifampicin Combinations

Dose^a^ | Proestrus | Estrus^b^ | Metestrus^b^ | Diestrus^b^
0 + 0 | 15 8 | 22 5 | 20 0 | 41 7
100 + 0 | 15 0 | 32 5 | 21 7 | 30 8
200 + 0 | 16 7 | 29 2 | 22 5 | 31 7
400 + 0 | 18 3 | 30 0 | 20 0 | 31 7
0 + 100 | 16 7 | 21 7 | 15 8 | 45 8
100 + 100 | 17 6 | 28 7 | 23 1 | 30 6
200 + 100 | 21 7 | 25 0 | 24 2 | 29 2
400 + 100 | 19 0 | 28 6 | 25 0 | 27 4
0 + 200 | 16 7 | 29 2 | 22 5 | 30 8
100 + 200 | 18 3 | 21 7 | 15 8 | 42 5
200 + 200 | 22 9 | 16 7 | 14 6 | 45 8
400 + 200^c^ | — | — | — | —
0 + 400 | 19 2 | 22 5 | 18 3 | 40 0
100 + 400^c^ | — | — | — | —
200 + 400^c^ | — | — | — | —
400 + 400^c^ | — | — | — | —

a Daily gavage doses of AZT + rifampicin (mg/kg per day)

b Results of a two-way analysis of variance show a significant interaction effect in the duration of estrus, metestrus, and diestrus, indicating that the dose response relationship of AZT differs across doses of rifampicin, data are presented as percent (%)

c Data were not available due to 100% mortality in this group

## Conclusions

AZT alone or rifampicin alone did not cause mortality. There was a dose-related increase in mortality with increasing doses of combinations of AZT and rifampicin. In general, female mice died earlier than males. Rifampicin alone caused significant and dose-related increases in liver weights, and AZT did not affect the increases in liver weights caused by rifampicin. Testis weights decreased with increasing dose of rifampicin, especially when given in combination with AZT.

AZT alone caused dose- and duration of treatment-related anemia, reticulocytopenia followed by reticulocytosis, thrombocytosis and leukopenia. Rifampicin alone caused mild but dose-related anemia and reticulocytopenia. Hematological toxicity in males and females increased with increasing dose and duration of treatment with AZT alone or in combination with rifampicin. Combinations of AZT and rifampicin resulted in hematological changes of far greater severity than those caused by either drug alone. Most or all mice treated with 400 mg rifampicin + 100, 200, or 400 mg AZT or 200 mg rifampicin+ 400 mg AZT either had severe anemia or died due to anemia, indicating that rifampicin synergized the hematological toxicity of AZT. Females were more sensitive to the hematological toxicity of combination therapies than the males. AZT alone did not cause significant changes in serum ALP and ALT activities. Rifampicin alone caused dose-related increases in ALP and ALT activities, indicating hepatotoxicity. AZT did not markedly influence the increases in serum ALP and ALT activities caused by rifampicin.

AZT alone caused dose-related bone marrow cellular depletion, and rifampicin alone did not cause consistent changes in bone marrow cellularity. Combination of AZT and rifampicin caused dose-related increases in severity of bone marrow cellular depletion, and bone marrow cellular depletion corresponded with decreases in blood erythrocyte counts. An increase in severity of cytoplasmic vacuolization of hepatocytes typical of fat vacuoles was observed in groups treated with rifampicin alone or in combination with AZT. In general, cytoplasmic vacuolization was more severe in male mice than in females. Hepatocyte cytoplasmic vacuolization corresponded with increases in liver weights and serum enzymes consistent with hepatotoxicity. Testicular degeneration was observed in groups treated with100, 200, or 400 mg AZT + 400 mg rifampicin and 400 mg AZT + 200 mg rifampicin. Testicular degeneration was generally associated with anemia and lower testis weights and sperm motility.