# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; lot 1401-R-9) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a powder. Rifampicin (lots 7232-150-03 and 122H2518) was procured from SAF Bulk Chemicals (St. Louis, MO) and supplied as a powder.

The relative purity of AZT was determined to be 99.7% by high-performance liquid chromatography. The purity of rifampicin was determined to be 97% to 98.5% by high-performance liquid chromatography. The vehicle used in this study was 0.1M potassium phosphate buffer. The potassium phosphate (lots 31183142 and 32181233) was manufactured by EM Science (Gibbstown, NJ).

## Dose Formulations

Dose formulations were prepared by combining both test articles with the vehicle. The formulations were then stirred until in solution or visually homogeneous. A stability study conducted on refrigerated formulations indicated no significant loss of either chemical for at least 30 days. Dose formulations for this study were refrigerated, protected from light, and used within 24 days. Samples at each dose level from the initial, midpoint, and final formulations were analyzed prior to dosing. The found concentrations of AZT ranged from 90% to 105% of the target concentrations; concentrations of rifampicin formulations were 85.6% to 106% of the target concentrations. Residual dosing formulations taken from the animal room after dosing with the midpoint and fmal mixes were also analyzed. Found concentrations of AZT and rifampicin in the residual formulations were 79% to 109% and 90% to 114% of the target concentrations, respectively.

## Study Design

B6C3F_1_ mice were obtained from a pathogen-free production colony of NIEHS at Taconic Farms (Germantown, NY), and were approximately 6 weeks old when placed on study. The mice were housed five per cage during quarantine before randomization and were housed individually (males) or five per cage (females) after randomization.

The mice were housed in polycarbonate cages with solid bottoms and sides. Average temperature in the animal room was 71.8° F, with a standard deviation of 1.0° F; average relative humidity was 58.1%, with a standard deviation of 3.9%.

At terminal sacrifice, blood samples were collected from five male and five female sentinel animals from both the core and clinical pathology study groups as part of the animal disease screening program. Results indicated that all animals were free of viral antibodies.

AIDS patients frequently receive rifampicin in combination with AZT to treat tuberculosis, one of the complicating opportunistic infections in these immunologically suppressed individuals. At present, no acceptable alternatives to animal models provide adequate toxicity information regarding this combination therapy. The AZT dose concentrations for this study were based on results of previous toxicity studies conducted in mice, which demonstrate that measurable evidence of toxicity will be obtained at levels of 200 and 400 mg AZT/kg per day. The human therapeutic dose for AZT is 10 mg/kg per day (PDR, 1996). The selected doses for this study were 100, 200, and 400 mg/kg body weight. These doses are 10, 20, and 40 times the human dose, but on a body surface area basis (Freirich et al., 1966), they are close to one, two, and four times the therapeutic dose. The human therapeutic dose for rifampicin is 600 mg per day (Editorial Staff, Drugs, 1971). The doses selected for this study are 100, 200, and 400 mg/kg body weight. On a body surface area basis (Freirich et al., 1966), these doses are approximately one, two, and four times the therapeutic dose.

A brief summary of the study design is provided in Table 2. The B6C3F_1_ mouse was selected as the experimental animal because this animal model is routinely utilized for toxicity evaluations of this type by the NIEHSINTP. The oral route of administration was selected for this study because it is the route used in humans. Combinations of AZT and rifampicin were administered by gavage as a single formulation in aqueous solution. The total daily dose was divided into two equal doses of 10 mL/kg given approximately 6 hours apart. The control group and the treated groups each consisted of 20 males and 20 females. Core animals (10 per group) were dosed until the day prior to sacrifice (91 to 94 days). Clinical pathology study animals (10 per group) were dosed until day 59. All mice were observed twice daily (morning and afternoon) for signs of mortality/moribundity.

Blood was drawn for clinical pathology evaluations on study days 4, 30, and 60 (clinical pathology study animals) or prior to sacrifice on study days 92 to 95 (core study animals). Vaginal cytology evaluations were conducted on all core study females on days 77 to 88, and sperm count, function, and motility were assessed on core study males on days 92 to 95. All surviving clinical pathology study animals were euthanatized on day 60 using 100% CO_2_ and discarded; all surviving core study animals were sacrificed on days 92 to 95 using 100% CO_2_.

### Clinical Pathology

All blood samples were collected from the retroorbital sinus under CO_2_/O_2_ (70/30) anesthesia. Blood for hematology analyses was collected into tubes containing EDTA, and blood for clinical chemistry analyses was collected into tubes without anticoagulant. Animals were selected in random order for blood collection, and samples were analyzed in the order collected.

Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin; mean cell hemoglobin (MCH); mean cell hemoglobin concentration (MCHC); mean cell volume (MCV); and leukocyte differentials were determined on whole blood using a Technicon H•1™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite Flow Cytometer™. Blood smears were prepared to manually verify leukocyte and platelet parameters if necessary. Alanine aminotransferase, aspartate aminotransferase, and alkaline phosphatase activities; bile acid concentrations; and sorbitol dehydrogenase activities were evaluated using a Roche Cobas Fara™ automated analyzer. Depending on the amount of each serum sample, the order of priority for clinical chemistry parameters were as listed above.

### Vaginal Cytology and Sperm Function Evaluations

Samples of vaginal fluid were taken from females using a medicine dropper moistened with neutral buffered saline. Samples from 12 consecutive days were placed on two slides per animal and were evaluated for relative frequency of estrous phases and the estrous cycle length.

Sperm motility was evaluated at necropsy in the following manner. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis) and weighed. Modified Tyrode’s buffer was applied to slides, and a small incision was made at the border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in buffered neutral saline solution. Caudae were fiely minced, and the tissue was incubated in the saline solution and then heat-fixed at 65° C. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, a testicular spermatid head count was determined by weighing the left testis, then removing the tunica albuginea and homogenizing the testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

A complete necropsy was performed on all core study animals and early death clinical pathology study animals. Selected organs (Table 2) from core study animals were weighed. Histopathology was conducted on the tissues listed in Table 2. Tissues were preserved in the appropriate fixative, trimmed to a maximum thickness of 0.3 cm for processing, embedded in paraffin, and sectioned at 4 to 6 μm. Testes were stained with PAS and other tissues were stained with hematoxylin and eosin. All tissues were examined by light microscopy.

TABLE 2 Experimental Design and Materials and Methods in the 13-Week Toxicity Study of AZT and Rifampicin Combinations in B6C3F_1_ Mice

- Study Laboratory; Southern Research Institute, Birmingham, AL; - Strain and Species; B6C3F_1_ mice; - Animal Source; Taconic Farms, Germantown, NY; - Time Held Before Study; 11 to 19 days; - Age When Placed on Study; 42 to 43 days; - Duration of Dosing; Core study 91 to 94 days; Clinical pathology study 59 days; - Necropsy Dates; Core study days 92 to 95; Clinical pathology study day 60; - Size of Study Groups; 10 males and 10 females; - Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups in random order; - Animals per Cage; One animal per cage (males) or five animals per cage (females); - Method of Animal Identification; Microchip implant (Biomedic Data Systems, Inc, Maywood, NJ); - Diet; NIH-07 pelleted feed (Zeigler Brothers, Inc, Gardners, PA), available ad libitum; - Water Distribution; Tap water (Birmingham, AL), available ad libitum via automatic watering system (Edstrom Industries, Inc, Waterford, WI); - Cages; Polycarbonate cages with solid bottoms and sides (Lab Products, Inc, Maywood, NJ); - Bedding; Heat-treated hardwood chips (Sam-Chips®, P J Murphy Forest Products Corporation, Montville, NJ); - Cage Filters; Remay® spun-bonded polyester (Andico, Birmingham, AL); - Racks; Stainless steel (Lab Products, Maywood, NJ); - Animal Room Environment; Temperature 71 8° ± 1 0° F; Relative humidity 58 1% ± 3 9%; Fluorescent light 12 hours fluorescent light/day; Room air minimum of 10 changes/hour; - Doses; Doses were administered 7 days a week in two equal doses approximately 6 hours apart. Daily doses in potassium phosphate buffer; 0 mg AZT + 0 mg rifampicin per kg body weight per day; 0 mg AZT + 100 mg rifampicin per kg body weight per day; 0 mg AZT + 200 mg rifampicin per kg body weight per day; 0 mg AZT + 400 mg rifampicin per kg body weight per day; 100 mg AZT + 0 mg rifampicin per kg body weight per day; 100 mg AZT + 100 mg rifampicin per kg body weight per day; 100 mg AZT + 200 mg rifampicin per kg body weight per day; 100 mg AZT + 400 mg rifampicin per kg body weight per day; 200 mg AZT + 0 mg rifampicin per kg body weight per day; 200 mg AZT + 100 mg rifampicin per kg body weight per day; 200 mg AZT + 200 mg rifampicin per kg body weight per day; 200 mg AZT + 400 mg rifampicin per kg body weight per day; 400 mg AZT + 0 mg rifampicin per kg body weight per day; 400 mg AZT + 100 mg rifampicin per kg body weight per day; 400 mg AZT + 200 mg rifampicin per kg body weight per day; 400 mg AZT + 400 mg rifampicin per kg body weight per day; - Type and Frequency of Observation; Mortahty/moribundity twice daily; Clinical findings once weekly (core study animals only); Body weights once weekly (weights reported for core study animals, clinical pathology study animals were weighed for dosing purposes only); - Method of Sacrifice; Carbon dioxide asphyxiation; - Necropsy; Complete necropsies were performed on all core study animals and early death clinical pathology study animals All tissues were fixed in formalin except the testes, which were fixed in Bourn’s fluid. The liver, right kidney, heart, lungs, thymus, and right testis were weighed for all core study mice sacrificed at the end of the study; - Histopathology; The following tissues from all mice in the 0 + 0 control group and the 200 + 200, 200 + 400, 400 + 200, and 400 + 400 groups and all mice that died early in the remaining groups were examined for histopathological changes adrenal glands, brain, clitoral glands, esophagus, femur, gallbladder, gross lesions, heart and aorta, large intestines, small intestines, kidneys, liver, lungs and bronchi, mandibular and mesenteric lymph nodes, mammary glands, nose, ovaries, pancreas, parathyroid glands, pituitary glands, prostate, salivary glands, seminal vesicle, spleen, stomach, testes with epididymis, thymus, thyroid gland, tissue masses, trachea, urinary bladder, and uterus Bone marrow, liver, spleen, thymus, testes, and gross lesions were evaluated from remaining mice in all other dose groups; - Clinical Pathology; Hematology and clinical chemistry evaluations were conducted on all core study animals at terminal sacrifice and on all clinical pathology animals on days 4, 30, and 60; Hematology: erythrocyte, reticulocyte, and platelet counts, hematocrit, hemoglobin, mean cell hemoglobin, mean cell hemoglobin concentration, mean cell volume, leukocyte counts and differentials, erythrocyte and platelet morphology (if necessary); Clinical Chemistry: alanine aminotransferase, aspartate aminotransferase, alkaline phosphatase, and sorbitol dehydrogenase and bile acid concentrations; - Sperm Morphology and Motility and Vaginal Cytology Evaluations; Sperm samples were collected from all core study males at terminal sacrifice The parameters evaluated included spermatid heads, spermatid counts, and motility The left epididymis and cauda epididymis were weighed Vaginal samples from 12 consecutive days were collected from all core study females The parameters evaluated included estrous phases and estrous cycle length

## Statistical Methods

Group means and standard deviations were calculated for final mean body weights, clinical pathology parameters, and organ weights. Organ-weight-to-body weight ratios were also calculated. Final mean body weights, mean organ weights, and organ-weight-to-body weight ratios for each dosed group were compared to those of the control group by a two-tailed Student’s t-test. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and dosed groups. Final mean body weights were also evaluated using Jonckheere’s (1954) test for trend; Williams’ (1971, 1972) test was applied if there was an indication of trend, and Dunnett’s (1955) test was used in the absence of a trend. Dunnett’s test was also used for evaluation of hematology data.

Sperm measurements were first analyzed for interaction using a nonparametric test. If the interaction was not statistically significant, averages were taken from each drug over the levels of the other drug, and control and dosed group means were evaluated using Jonckheere’s (1954) test for trend; Williams’ (1971, 1972) test was applied if there was an indication of trend, and Dunnett’s (1955) test was used in the absence of a trend. The outlier test of Dixon and Massey (1951) was used to detect extreme values. Implausible values, extreme values from animals that were suspected of being sick due to causes other than treatment, and values that were indicated to be inadequate due to measurement problems were eliminated from analysis. Final mean body weights and organ weights associated with sperm measurements were evaluated using a two-way analysis of variance.

Treatment effects on vaginal cytology data were investigated by applying a multivariate analysis of variance (using Wilke’s Criterion [Stevens, 1986] as the test statistic) to test for the simultaneous equality of measurements across dose concentrations. Since the data are proportions (the proportion of the observation period that an animal was in a given estrous phase), an arcsine transformation was used to bring the data into closer conformance with the normality assumptions required for the multivariate analysis of variance.

Severity grades for lesions in liver, spleen, thymus, testes, and bone marrow were analyzed for interaction using a two-way analysis of variance. Dunnett’s (1955) test was used to detect treatment-related effects.