# Introduction

Acquired immunodeficiency syndrome (AIDS) is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegle et al., 1981). The etiological agent of AIDS is a retrovirus that is now referred to as the human immunodeficiency virus (HIV) (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compounds, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in life span (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss CD-1® mice were dosed daily by gavage with AZT doses of 100, 250, 500, or 1,000 mg/kg for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at 1,000 mg/kg. Pathologic findings in the AZT-treated mice were consistent with the hematological results and included lymphoid depletion, reticuloendothelial hyperplasia in spleen and thymus, and bone marrow hypocellularity.

In a 14-week subchronic study (NTP, 1999), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg of AZT/kg body weight in 0.5% methylcellulose by gavage. All doses were administered twice daily as one half of the total daily dose. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups were administered doses of 0, 50, 400, or 1,000 mg of AZT/kg twice daily for 14 weeks and then held without additional treatment for 29 days. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical observation that affected AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and/or muzzle (Rao et al., 1998).

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve (AUC) obtained from an oral dose to that of an intravenous dose at the same concentration (Trang et al., 1993). Bioavailability (F) was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life (t_1/2_) values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose-proportional over the oral dose concentration range.

Standard teratology tests of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g or 76 times the antiviral ID_50_. Rabbits were orally dosed at 125 to 500 mg/kg on gestation days 6 to 18, and no fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g or 50 times the antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal weight gain, food consumption, hematological parameters, and growth or survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female C3H/He mice were exposed to 0, 0.25, 0.5, or 2.5 mg/mL of AZT in the drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryo lethality was observed.

Since AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992). As a result, the treatment of AIDS is increasingly one of combination therapy of antiretroviral drugs and antimicrobial drugs (Goldschmidt and Dong, 1992). Tuberculosis (TB) is one of the opportunistic diseases leading to mortality in AIDS patients (Nolan, 1992). AIDS patients with TB receive combination therapy with AZT and antituberculosis drugs. Treatment for TB involves combination therapy with multiple antibacterial agents in order to eliminate the strains of organisms inducing TB, including those resistant to isoniazid, the primary drug used in treating TB. The standard treatment regimen is isoniazid (300 mg), rifampicin (600 mg, or 450 mg for persons weighing less than 50 kg), and pyrazinamide (20 to 30 mg/kg) for the first 2 months of treatment. Isoniazid and rifampicin are continued for another 7 months, for a total therapy duration of 9 months (CDC, 1987; Barnes et al., 1991).

Rifampicin is a well-tolerated drug (Editorial Staff, Drugs, 1971). The most serious problem is the development of jaundice (Scheuer et al., 1974). Sixteen deaths associated with this reaction have been recorded in 500,000 treated patients. Hepatitis from rifampicin seldom occurs in patients with normal hepatic function. Similarly, the combination of isoniazid and rifampicin appears to be safe in patients with normal hepatic function (Grosset and Levintis, 1983). Chronic liver disease, alcoholism, and old age appear to increase the incidence of severe hepatic problems when rifampicin is given alone or concurrently with isoniazid (Gronhagen-Riska et al., 1978).

Administration of rifampicin on an intermittent schedule (twice weekly or less) is associated with frequent adverse effects, and rifampicin should not be used in this manner. A flu-like syndrome with fever, chills, and myalgia develops in 20% of patients treated in this way. The syndrome may also include eosinophilia, interstitial nephritis, acute tubular necrosis, thrombocytopenia, hemolytic anemia, and shock (Girling and Hitze, 1979).

Rifampicin [rifampin, 3-4-methylpiperazinyl-1-iminomethylrifamycin SV] is a semisynthetic derivative of rifamycin-B, which is one of a group of antibiotics produced by Streptomyces mediterranei (Radner, 1973). Rifampicin is a tasteless, red-orange, crystalline powder (Binda et al., 1971; IARC, 1986). Rifampicin has the molecular formula C_43_H_58_N_4_O_12_, a molecular weight of 823, and decomposes at 183° C to 188° C. It is highly soluble in methanol, ethyl acetate, chloroform, DMSO, methylene chloride, and tetrahydrofuran and is slightly soluble in acetone and CCl_4_. Water solubility (25° C) is 0.28% at pH 7.5 and 9.95% at pH 2.0. Rifampicin is a “zwitterion” with a pK_a_ 1.7 related to the 4-hydroxy and a pK_a_ 7.9 related to the 3-piperazine nitrogen group at position 3. It is stable in dimethylsulfoxide and relatively stable in water at different pH levels. The stability curves have been determined at pH 2.3 and 8.0. In acid medium (pH 2.3), slight hydrolysis occurs with release of 1-amino-4-methylpiperazine and formation of 3-formyl rifamycin SV; at pH levels above 7.0, and in the presence of atmospheric oxygen, rifampicin is oxidized in small quantities to rifampicin quinone. This reaction may be prevented by adding ascorbic acid.

Rifampicin at a concentration of 0.5 μg/mL inhibits the growth of Mycobacterium tuberculosis in vitro. This is an easily achieved serum level because, when given orally, this antibiotic is readily absorbed on an empty stomach. A single 600 mg dose given on an empty stomach produces blood levels many times that needed to inhibit tubercle bacilli in vitro, and the level is maintained for 12 to 24 hours (Radner, 1973). The oral administration of rifampicin produces peak concentrations in plasma in 2 to 4 hours; after ingestion of 600 mg, this value is approximately 71 μg/mL, but there can be considerable variance. Para-aminosalicylic acid (PAS) may delay the absorption of rifampicin and adequate plasma concentrations may not be reached. Ifthese agents are concurrently used, they should be separately administered at an interval of 8 to 12 hours (Radner, 1973).

The principal metabolite of rifampicin found in humans is the deacetylated form that is also active against M tuberculosis (Furesz, 1970). Rifampicin diffuses readily and penetrates tissues such as lung, liver, kidney, and bone. High levels have been demonstrated in the lung (including the walls of tuberculous cavities), liver, urine, and spinal fluid in patients receiving one daily oral dose. Animal experiments using small doses of rifampicin have demonstrated two peaks in the blood levels; the second peak is due to reabsorption of the drug from the bile. Higher dosage results in such high blood levels that the second peak is obscured. After 6 hours, almost 100% of the rifampicin in the bile is in the deacetylated form; in urine, deacetylated rifampicin represents 30 to 60% of total rifampicin (Furesz, 1970). Intestinal reabsorption is affected bythe presence of food as well as deacetylation; thus enterohepatic circulation does not indefinitely continue (Curci, 1969). Rifampicin is slowly excreted. The duration of blood levels varies in different animal species. Blood levels disappear within 24 hours in rats and guinea pigs, but in dogs, even small doses lead to detectable blood levels for as long as 56 hours. Studies performed on organs of patients show penetration of rifampicin in all examined organs, and higher concentrations are found in the lung than in the serum. Biliary concentrations reach about 10 times the blood levels, whereas urine concentrations are usually more than twice the biliary levels (Radner, 1973).

The LD_50_ in the mouse following oral administration in different vehicles was 1,220 and 1,445 mg/kg within 24 hours (Editorial Staff, Drugs, 1971). The values obtained within 5 days were 885 mg/kg using oral, 640 mg/kg using intraperitoneal, and 260 mg/kg using intravenous administration. The LD_50_ values in the rat were 1,720 mg/kg with oral, 550 mg/kg with intraperitoneal, and 330 mg/kg with intravenous administration. The LD_50_ value in the guinea pig was 639 mg/kg with intraperitoneal administration and in the rabbit was 2,120 mg/kg with oral administration (Furesz, 1970).

In rats, administration of 400 mg/kg per day rifampicin by gastric intubation for 8 days produced a transient decrease in body weight, anorexia, apathy, ataxia, and marked dorsal hair loss. This dose of rifampicin induced fatty liver and a significant increase in the total cholesterol in the livers of male and female rats and in total lipids and triglycerides in the livers of female rats (Piriou et al., 1979).

In a 4-week toxicity study, rabbits that received 400 mg/kg body weight per day by oral administration exhibited significant weight decrease and severe jaundice, together with fatty and hydropic degeneration of the liver and kidneys (Furesz, 1970).

There was no appreciable toxicity evident in rats given 50 or 100 mg/kg body weight daily by oral administration for 26 weeks, but 200 mg/kg caused dose-related histological changes of the liver (slight increase of liver weight, slight cloudy swelling, and hydropic degeneration in liver). There were no adverse effects in rabbits given 100 mg/kg body weight daily by oral administration for 4 weeks, but overt toxicity (mortality 3 of 5), including jaundice and fatty and hydropic degenerations of liver and kidneys, occurred at a dose of 400 mg/kg body weight over the same period (Editorial Staff, Drugs, 1971).

Results of animal studies suggest that a combination of rifampicin-isoniazid can produce liver damage, whereas rifampicin alone does not. Hugues et al. (1969) found no histological evidence of hepatic lesions in control rats or in rats treated with rifampicin alone at a daily dose of 15 or 30 mg/kg body weight. The addition of isoniazid (5 mg/kg body weight) to these dosages of rifampicin resulted in severe hepatocellular lesions in 7 of31 animals after 2 weeks of treatment. Weight loss and general debility, although present in all seven rats, were more severe in those given the higher dose of rifampicin. Fatty degeneration and hepatic enlargement occurred in 2 of the 31 rats treated with isoniazid (5 mg/kg body weight) alone.

Rifampicin has been associated with a significant increase in hepatomas in female C3Hf mice (Della Porta et al., 1978). An increased incidence of tumors did not occur in male and female Wistar rats treated with rifampicin in the drinking water for 104 weeks (Della Porta et al., 1978). In a one-year study, malignant tumors did not occur in male and female BALB/c mice given 20 subcutaneous injections of 0.3 mg of rifampicin in saline (Bichel, 1973). Rifampicin has been suspected of teratogenicity and embryotoxicity because of results from rodent studies, but there is no proof of damages to children when moderate therapeutic doses are administered (Warkany, 1979)

## Study Rationale

Tuberculosis is a common opportunistic infection in AIDS patients. AIDS patients with TB receive combination therapy of antiretroviral drug AZT with antibacterial drugs such as rifampicin. Information on toxicity of AZT alone and rifampicin alone is available. However, toxic potential of AZT with rifampicin combination therapy in animal models is not available. This subchronic toxicity study of the combination of AZT and rifampicin in animal models was conducted by the NIEHS as a part of the program to evaluate the toxicity of drugs, especially combination therapies used in the treatment of AIDS patients with opportunistic infections.