# APPENDIX A Clinical Pathology Results

TABLE A1 Hematology Data for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | WBC^b^ (10^3^/mm^3^) | RBC (10^6^/mm^3^) | Hgb (g/dL) | Hct (%) | MCV (fL) | MCH (Pg) | MCHC (g/dL) | Platelets (10^3^/mm^3^) | Reticulocytes (10^5^/mm^3^) | Neutrophils (10^3^/mm^3^) | Lymphocytes (10^3^/mm^3^) | Monocytes (10^3^/mm^3^) | Eosinophils (10^3^/mm^3^) | Basophils (10^3^/mm^3^) | LUC (10^3^/mm^3^)
Day 4
0 + 0^c^ | 5 67 | 9 61 | 15 9 | 47 6 | 49 5 | 16 5 | 33 3 | 1,310 | 3 6 | 0 46 | 4 95 | 0 14 | 0 09 | 0 02 | 0 02
| 0 803 | 0 566 | 0 85 | 2 92 | 1 15 | 0 20 | 0 77 | 227 9 | 0 92 | 0 124 | 0 719 | 0 048 | 0 035 | 0 005 | 0 011
100 + 0 | 5 26 | 9 34 | 15 5 | 46 2 | 49 5 | 16 6 | 33 6 | 1,384 | 2 7^**^ | 0 47 | 4 57 | 0 13 | 0 06 | 0 01 | 0 02^c^
| 0 995 | 0 455 | 0 63 | 2 60 | 1 46 | 0 24 | 1 34 | 186 4 | 0 83 | 0 208 | 0 811 | 0 039 | 0 023 | 0 009 | 0 007
200 + 0^c^ | 5 85 | 9 38 | 15 6 | 46 5 | 49 6 | 16 6 | 33 5 | 1,490 | 2 5^**^ | 0 55 | 5 06 | 0 16 | 0 08 | 0 01 | 0 02^e^
| 0 842 | 0 347 | 0 55 | 2 48 | 1 49 | 0 13 | 1 08 | 159 9 | 0 60 | 0 249 | 0 680 | 0 084 | 0 042 | 0 007 | 0 008
400 + 0 | 5 68 | 9 38 | 15 6 | 46 2 | 49 2 | 16 6 | 33 8 | 1,387 | 2 1^**^ | 0 43 | 4 97 | 0 17 | 0 08 | 0 02 | 0 02
| 0 932 | 0 313 | 0 54 | 2 22 | 1 45 | 0 17 | 1 04 | 155 4 | 0 63 | 0 173 | 0 695 | 0 067 | 0 030 | 0 009 | 0 011
0+100 | 5 88 | 9 53 | 15 6 | 46 6 | 48 9 | 163 | 33 5 | 1,462 | 2 5^**^ | 0 58 | 5 02 | 0 17 | 0 08 | 0 01 | 0 02
| 0 786 | 0 429 | 0 68 | 1 79 | 1 28 | 0 15 | 1 01 | 194 8 | 0 83 | 0 166 | 0 697 | 0 053 | 0 030 | 0 005 | 0 008
100+100 | 5 71 | 9 28 | 15 3 | 45 9 | 49 5 | 16 5 | 33 3 | 1,499 | 2 0^**^ | 0 50 | 4 94 | 0 17 | 0 08 | 0 01 | 0 02
| 0 749 | 0 299 | 0 43 | 1 84 | 1 43 | 0 20 | 1 12 | 112 3 | 0 52 | 0 135 | 0 591 | 0 050 | 0 036 | 0 008 | 0 006
200 + 100 | 5 67 | 9 13 | 15 1 | 44 5 | 48 7 | 16 5 | 33 9 | 1,484 | 1 3^**^ | 0 56 | 4 85 | 0 14 | 0 09 | 0 02 | 0 02^c^
| 0 950 | 0 445 | 0 69 | 2 34 | 0 91 | 0 20 | 0 88 | 167 6 | 0 25 | 0 365 | 0 746 | 0 038 | 0 044 | 0 016 | 0 010
400 + 100 | 4 81 | 9 04 | 15 0 | 44 3 | 49 0 | 16 5 | 33 8 | 1,390 | 1 3^**^ | 0 41 | 4 19 | 0 12 | 0 07 | 0 01 | 0 02
| 1 159 | 0 368 | 0 58 | 1 61 | 1 02 | 0 19 | 0 57 | 162 1 | 0 40 | 0 155 | 1 015 | 0 030 | 0 028 | 0 006 | 0 008
0 + 200 | 5 63 | 9 26 | 15 3 | 45 5 | 49 3 | 16 5 | 33 6 | 1,579 | 1 9^**^ | 0 68 | 4 74 | 0 12 | 0 07 | 0 01 | 0 02^c^
| 0 580 | 0 519 | 0 78 | 1 81 | 1 36 | 0 25 | 1 04 | 172 3 | 0 47 | 0 213 | 0 682 | 0 048 | 0 025 | 0 007 | 0 010
100 + 200 | 4 67 | 9 44 | 15 5 | 46 0 | 48 8 | 16 5 | 33 8 | 1,509 | 1 1^**^ | 0 40 | 4 03 | 0 12 | 0 08 | 0 01 | 0 01
| 0 781 | 0 364 | 0 71 | 2 07 | 1 33 | 0 14 | 1 05 | 209 0 | 0 38 | 0 092 | 0 738 | 0 028 | 0 024 | 0 003 | 0 005
200 + 200^c^ | 4 69 | 9 19 | 15 2 | 44 9 | 48 8 | 16 6 | 34 0 | 1,487 | 1 0^*^,^e^ | 0 50 | 3 96^*^ | 0 11 | 0 09 | 0 01 | 0 01
| 1 155 | 0 254 | 0 45 | 1 47 | 1 57 | 0 17 | 1 30 | 1144 | 0 35 | 0 113 | 1 125 | 0 020 | 0 039 | 0 010 | 0 009
400 + 200 | 5 12 | 9 43 | 15 6 | 46 3 | 49 1 | 16 6 | 33 8 | 1,445 | 1 0^**^ | 0 43 | 4 49 | 0 09 | 0 09 | 0 02 | 0 01^c^
| 0 596 | 0 266 | 0 47 | 1 57 | 0 82 | 0 22 | 0 78 | 180 4 | 0 29 | 0 131 | 0 489 | 0 027 | 0 028 | 0 010 | 0 009
0 + 400^c^ | 5 13 | 9 75 | 16 1 | 47 7 | 49 0 | 16 5 | 33 7 | 1,598 | 1 4^**^,^e^ | 0 68 | 4 21 | 0 12 | 0 09 | 0 01 | 0 01
| 0 756 | 0 432 | 0 70 | 2 14 | 1 12 | 0 32 | 1 00 | 241 7 | 0 43 | 0 254 | 0 629 | 0 042 | 0 052 | 0 005 | 0 007
100 + 400 | 4 57 | 9 56 | 15 9 | 47 0 | 49 2 | 16 7 | 33 9 | 1,475 | 0 8^**^ | 0 61 | 3 72^**^ | 0 13 | 0 09 | 0 01 | 0 01
| 0 917 | 0 257 | 0 32 | 1 94 | 1 86 | 0 27 | 1 17 | 162 2 | 0 39 | 0 227 | 0 760 | 0 065 | 0 048 | 0 005 | 0 004
200 + 400 | 5 92 | 9 34 | 15 5 | 45 7 | 48 9 | 16 6 | 33 9 | 1,519 | 0 8^**^,^c^ | 1 55 | 4 12 | 0 15 | 0 07 | 0 02 | 0 02
| 3 069 | 0 652 | 1 16 | 3 54 | 1 71 | 0 27 | 1 59 | 197 4 | 0 32 | 3 150 | 0 356 | 0 061 | 0 028 | 0 008 | 0 008
400 + 400 | 4 95 | 9 41 | 15 5 | 46 1 | 49 0 | 16 5 | 33 6 | 1,470 | 0 9^**^ | 0 56 | 4 20 | 0 11 | 0 06 | 0 01 | 0 02^e^
| 0 846 | 0 313 | 0 52 | 1 44 | 1 04 | 0 20 | 0 98 | 184 5 | 0 29 | 0 194 | 0 800 | 0 068 | 0 039 | 0 007 | 0 005
Day 30
0 + 0^c^ | 7 05 | 9 64 | 15 8 | 47 0 | 48 8 | 16 4 | 33 7 | 1,427 | 3 5 | 0 78 | 5 84 | 0 20 | 0 18 | 0 03 | 0 02
| 1 755 | 0 172 | 0 29 | 1 02 | 0 78 | 0 26 | 0 50 | 124 0 | 0 22 | 0 272 | 1 410 | 0 062 | 0 066 | 0 012 | 0 007
100 + 0^c^ | 6 61 | 8 63 | 15 3 | 45 7 | 52 9^**^ | 17 7^**^ | 33 5 | 1,405 | 4 4 | 0 80 | 5 43 | 0 18 | 0 15 | 0 02 | 0 02
| 1 361 | 0 169 | 0 29 | 1 31 | 1 25 | 0 37 | 0 56 | 82 2 | 0 58 | 0 137 | 1 203 | 0 039 | 0 045 | 0 007 | 0 011
200 + 0^c^ | 5 60 | 8 32^*^ | 15 0 | 45 0 | 54 1^**^ | 18 1^**^ | 33 4 | 1,505 | 4 0 | 0 69 | 4 60 | 0 12^*^ | 0 16 | 0 02 | 0 02^e^
| 1 845 | 0 194 | 0 33 | 1 47 | 1 53 | 0 44 | 0 59 | 124 6 | 1 07 | 0 347 | 1 394 | 0 076 | 0 091 | 0 011 | 0 007
400 + 0 | 6 33 | 8 06^**^ | 14 8 | 44 9 | 55 7^**^ | 18 4^**^ | 33 0 | 1,444 | 5 7 | 0 74 | 5 22 | 0 17 | 0 17 | 0 02 | 0 02
| 1 162 | 0 304 | 0 38 | 1 31 | 1 46 | 0 40 | 0 34 | 117 5 | 0 97 | 0 132 | 1 011 | 0 036 | 0 038 | 0 007 | 0 005
0 + 100^c^ | 7 11 | 9 72 | 15 5 | 46 3 | 47 6 | 16 0 | 33 6 | 1,458 | 3 5 | 0 95 | 5 78 | 0 18 | 0 17 | 0 02 | 0 02
| 1 541 | 0 292 | 0 56 | 1 51 | 0 61 | 0 29 | 0 35 | 187 0 | 0 55 | 0 365 | 1 173 | 0 051 | 0 064 | 0 007 | 0 007
100 + 100 | 7 20 | 8 59 | 14 9 | 44 8 | 52 2^**^ | 17 4^**^ | 33 3 | 1,552 | 4 7 | 0 98 | 5 81 | 0 20 | 0 16 | 0 02 | 0 02
| 0 828 | 0 203 | 0 39 | 1 45 | 1 31 | 0 35 | 0 66 | 86 9 | 0 58 | 0 313 | 0 692 | 0 042 | 0 042 | 0 007 | 0 009
200 + 100 | 6 61 | 8 14^**^ | 14 6 | 44 6 | 54 8^**^ | 18 0^**^ | 32 8 | 1,473 | 6 1 | 0 84 | 5 39 | 0 17 | 0 17 | 0 02 | 0 02
| 1 261 | 0 277 | 0 47 | 1 78 | 0 90 | 0 47 | 0 66 | 62 9 | 0 98 | 0 203 | 1 052 | 0 028 | 0 048 | 0 011 | 0 007
400 + 100^c^ | 6 35 | 7 77^**^ | 14 0 | 42 6 | 54 9^**^ | 18 1^**^ | 32 9 | 1,563 | 7 4^*^,^e^ | 0 91 | 5 02 | 0 18 | 0 20 | 0 02 | 0 01
| 1 466 | 0 217 | 0 45 | 1 33 | 0 77 | 0 33 | 0 37 | 127 2 | 0 82 | 0 357 | 1 057 | 0 068 | 0 088 | 0 008 | 0 007
0 + 200^c^ | 7 66 | 9 60 | 15 3 | 45 7 | 47 6 | 16 0 | 33 6 | 1,514 | 3 7 | 1 02 | 6 23 | 0 22 | 0 16 | 0 02 | 0 02
| 1 653 | 0 247 | 0 35 | 0 95 | 0 67 | 0 29 | 0 37 | 70 0 | 0 28 | 0 230 | 1 578 | 0 046 | 0 037 | 0 012 | 0 007
100 + 200^e^ | 7 66 | 8 21^**^ | 14 5 | 43 6 | 53 2^**^ | 17 6^**^ | 33 2 | 1,581 | 6 7 | 1 10 | 6 12 | 0 20 | 0 20 | 0 03 | 0 02
| 1 457 | 0 248 | 0 40 | 0 93 | 1 04 | 0 30 | 0 53 | 75 8 | 1 02 | 0 346 | 1 164 | 0 057 | 0 059 | 0 012 | 0 007
200 + 200^f^ | 6 80 | 7 86^**^ | 13 8 | 42 1 | 53 6^**^ | 17 5^**^ | 32 7 | 1,658 | 6 9 | 0 87 | 5 53 | 0 18 | 0 18 | 0 02 | 0 01
| 0 859 | 0 162 | 0 25 | 1 15 | 1 13 | 0 38 | 0 95 | 126 3 | 0 95 | 0 092 | 0 805 | 0 039 | 0 045 | 0 010 | 0 005
400 + 200^e^ | 5 77 | 4 71^**^ | 8 2^**^ | 24 9^**^ | 50 4 | 17 0 | 33 8 | 2,255^**^ | 8 5^**^ | 0 95 | 4 53 | 0 14 | 0 12 | 0 01 | 0 02
| 0 863 | 2 769 | 5 09 | 16 19 | 5 08 | 0 92 | 1 69 | 435 0 | 8 44 | 0 240 | 0 694 | 0 027 | 0 093 | 0 005 | 0 012
0 + 400^e^ | 7 52 | 9 41 | 14 7 | 43 6 | 46 3 | 15 6^**^ | 33 7 | 1,601 | 3 4 | 0 96 | 6 17 | 0 17 | 0 19 | 0 02 | 0 02
| 1269 | 0 221 | 0 40 | 1 26 | 0 73 | 0 24 | 0 36 | 120 4 | 1 06 | 0 215 | 1 110 | 0 033 | 0 051 | 0 005 | 0 009
100 + 400^e^ | 5 53 | 4 81^**^ | 8 2^**^ | 23 9^**^ | 48 8 | 16 9 | 34 7 | 2,147^**^ | 5 6 | 0 87 | 4 43 | 0 12^*^ | 0 06^**^ | 0 01 | 0 02
| 1 753 | 1 743 | 3 02 | 9 83 | 3 28 | 0 48 | 1 65 | 239 8 | 4 64 | 0 382 | 1 464 | 0 034 | 0 026 | 0 005 | 0 012
200 + 400^f^ | 5 90 | 2 56^**^ | 4 2^**^ | 12 0^**^ | 46 9 | 16 4 | 35 1^*^ | 2,359^**^ | 2 0^h^ | 1 05 | 4 64 | 0 13 | 0 04^**^ | 0 01 | 0 04^h^
| 2 034 | 0 410 | 0 70 | 2 33 | 2 01 | 0 33 | 1 03 | 410 2 | 0 65 | 0 541 | 1 758 | 0 079 | 0 018 | 0 010 | 0 016
400 + 400^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
Day 60
0 + 0^c^ | 4 81 | 10 16 | 16 7 | 47 8 | 47 0 | 16 5 | 35 0 | 1,073 | 3 6 | 0 52 | 4 06 | 0 11 | 0 10 | 0 01 | 0 01
| 1 076 | 0 413 | 0 77 | 2 02 | 0 65 | 0 35 | 0 52 | 144 6 | 0 33 | 0 228 | 0 872 | 0 022 | 0 045 | 0 010 | 0 006
100 + 0^c^ | 5 15 | 8 77^**^ | 15 6^**^ | 44 9^**^ | 51 2^**^ | 17 8^**^ | 34 7 | 1,216 | 3 8^e^ | 0 55 | 4 40 | 0 09 | 0 09 | 0 01 | 0 01
| 0 755 | 0 256 | 0 42 | 1 47 | 0 59 | 0 26 | 0 47 | 111 1 | 0 38 | 0 097 | 0 677 | 0 016 | 0 038 | 0 005 | 0 005
200 + 0^c^ | 4 55 | 8 34^**^ | 15 4^**^ | 44 8^**^ | 53 7^**^ | 18 4^**^ | 34 3^*^ | 1,384^**^ | 4 2 | 0 47 | 3 88 | 0 07 | 0 10 | 0 01 | 0 01
| 0 729 | 0 349 | 0 60 | 1 78 | 0 92 | 0 24 | 0 33 | 278 7 | 0 35 | 0 108 | 0 662 | 0 019 | 0 065 | 0 007 | 0 005
400 + 0 | 4 82 | 7 99^**^ | 14 8^**^ | 43 8^**^ | 54 8^**^ | 18 6^**^ | 34 0^**^ | 1,520^**^ | 4 5^**^ | 0 49 | 4 15 | 0 08 | 0 07 | 0 01 | 0 01
| 0 909 | 0 286 | 0 53 | 1 34 | 0 90 | 0 17 | 0 51 | 250 0 | 0 32 | 0 161 | 0 727 | 0 027 | 0 032 | 0 006 | 0 005
0 + 100^c^ | 5 49 | 10 06 | 15 8^**^ | 45 8 | 45 6^**^ | 15 7^**^ | 34 6 | 1,240 | 3 3 | 0 81^**^ | 4 44 | 0 11 | 0 09 | 0 01 | 0 01
| 0 802 | 0 249 | 0 30 | 1 11 | 0 77 | 0 18 | 0 48 | 81 8 | 0 36 | 0 219 | 0 633 | 0 034 | 0 027 | 0 004 | 0 010
100 + 100 | 5 08 | 8 74^**^ | 15 1^**^ | 43 9^**^ | 50 3^**^ | 17 3^**^ | 34 3^*^ | 1,443^**^ | 3 9 | 0 70 | 4 17 | 0 09 | 0 10 | 0 01 | 0 01
| 0 781 | 0 418 | 0 60 | 1 97 | 0 51 | 0 28 | 0 39 | 133 9 | 0 41 | 0 189 | 0 589 | 0 029 | 0 037 | 0 003 | 0 005
200 + 100 | 4 63 | 7 97^**^ | 14 4^**^ | 42 7^**^ | 53 6^**^ | 18 1^**^ | 33 7^**^ | 1,501^**^ | 4 4^**^ | 0 56 | 3 89 | 0 07 | 0 09 | 0 01 | 0 01
| 0 839 | 0 195 | 0 22 | 1 15 | 0 98 | 0 29 | 0 61 | 210 4 | 0 53 | 0 236 | 0 647 | 0 025 | 0 033 | 0 006 | 0 013
400 + 100^c^ | 4 27 | 7 38^**^ | 13 8^**^ | 41 0^**^ | 55 6^**^ | 18 7^**^ | 33 6^**^ | 1,751^**^ | 5 5^**^,^e^ | 0 48 | 3 62 | 0 06^**^ | 0 09 | 0 01 | 0 01^e^
| 0 787 | 0 379 | 0 68 | 1 65 | 0 90 | 0 37 | 0 78 | 178 4 | 0 55 | 0 137 | 0 765 | 0 017 | 0 042 | 0 006 | 0 005
0 + 200^c^ | 6 40 | 9 79 | 15 1^**^ | 44 1^**^ | 45 0^**^ | 15 5^**^ | 34 3^*^ | 1,287 | 3 2 | 0 78^*^ | 5 38 | 0 12 | 0 10 | 0 02 | 0 01
| 1 674 | 0 415 | 0 49 | 1 59 | 0 69 | 0 19 | 0 50 | 113 8 | 0 27 | 0 220 | 1 466 | 0 026 | 0 055 | 0 007 | 0 005
100 + 200^e^ | 5 14 | 8 19^**^ | 13 9^**^ | 41 0^**^ | 50 1^**^ | 17 0^**^ | 33 9^**^ | 1,672^**^ | 3 4 | 0 58 | 4 40 | 0 07 | 0 07 | 0 01 | 0 01
| 0 721 | 0 336 | 0 61 | 1 55 | 0 67 | 0 14 | 0 58 | 185 9 | 0 27 | 0 124 | 0 631 | 0 015 | 0 017 | 0 004 | 0 009
200 + 200^f^ | 4 55 | 7 51^**^ | 13 3^**^ | 39 1^**^ | 52 1^**^ | 17 6^**^ | 33 8^**^ | 1,955^**^ | 4 6^**^ | 0 53 | 3 88 | 0 07^*^ | 0 06 | 0 01 | 0 01
| 0 669 | 0 304 | 0 49 | 1 26 | 0 79 | 0 16 | 0 29 | 157 1 | 0 68 | 0 129 | 0 650 | 0 010 | 0 010 | 0 006 | 0 005
400 + 200^i^ | 5 07 | 7 09^**^ | 12 6^**^ | 37 1^**^ | 52 4^**^ | 17 8^**^ | 34 0^*^ | 2,313^**^ | 4 4^k^ | 0 65 | 4 26 | 0 07 | 0 07 | 0 01 | 0 01
| 0 663 | 0 473 | 0 64 | 2 63 | 1 28 | 0 27 | 1 04 | 104 8 | 1 33 | 0 178 | 0 449 | 0 029 | 0 021 | 0 000 | 0 005
0 + 400^f^ | 5 77 | 9 55^**^ | 14 2^**^ | 41 5^**^ | 43 4^**^ | 14 9^**^ | 34 3 | 1,273 | 2 9^*^,^h^ | 0 79^*^ | 4 76 | 0 09 | 0 10 | 0 01 | 0 01
| 1 622 | 0 443 | 0 60 | 1 62 | 0 35 | 0 13 | 0 29 | 92 3 | 0 58 | 0 251 | 1 322 | 0 048 | 0 097 | 0 008 | 0 000
100 + 400^j^ | 4 58 | 7 40^**^ | 12 2^**^ | 36 0^**^ | 48 5 | 16 4 | 33 9^*^ | 2,052^**^ | 2 2^**^ | 0 51 | 3 97 | 0 05^*^ | 0 04 | 0 02 | 0 02
| 0 276 | 0 071 | 0 42 | 1 06 | 0 99 | 0 42 | 0 21 | 97 6 | 0 21 | 0 064 | 0 177 | 0 007 | 0 021 | 0 007 | 0 007
200 + 400^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
400 + 400^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
Days 92 to 95
0 + 0^c^ | 5 80 | 9 86 | 15 5 | 46 0 | 46 7 | 15 7 | 33 6 | 1,146 | 4 9^e^ | 0 67 | 4 88 | 0 12 | 0 11 | 0 02 | 0 01
| 0 964 | 0 762 | 1 23 | 3 31 | 1 56 | 0 31 | 0 65 | 202 0 | 2 48 | 0 261 | 0 697 | 0 040 | 0 045 | 0 010 | 0 011
100 + 0^c^ | 4 88 | 8 40^**^ | 14 7 | 44 3 | 52 7^**^ | 17 5^**^ | 33 1 | 1,315 | 4 3^f^ | 0 57 | 4 11 | 0 08 | 0 10 | 0 01 | 0 01
| 1 144 | 0 392 | 0 88 | 2 78 | 1 43 | 0 42 | 0 85 | 115 1 | 0 31 | 0 161 | 0 974 | 0 023 | 0 054 | 0 005 | 0 011
200 + 0^c^ | 4 53 | 8 01^**^ | 14 7 | 44 6 | 55 7^**^ | 18 3^**^ | 32 9 | 1,206 | 4 8 | 0 53 | 3 72 | 0 08 | 0 18 | 0 01 | 0 01
| 0 946 | 0 322 | 0 50 | 1 64 | 1 95 | 0 47 | 0 81 | 457 3 | 0 32 | 0 271 | 0 897 | 0 049 | 0 211 | 0 007 | 0 008
400 + 0 | 5 14 | 7 41^**^ | 13 8^**^ | 42 4^*^ | 57 2^**^ | 18 7^**^ | 32 6^*^ | 1,479 | 5 7 | 0 53 | 4 39 | 0 08 | 0 12 | 0 01 | 0 01
| 1 176 | 0 390 | 0 81 | 2 99 | 1 49 | 0 40 | 0 58 | 163 9 | 0 50 | 0 161 | 0 994 | 0 036 | 0 043 | 0 007 | 0 008
0 + 100^c^ | 5 47 | 9 95 | 14 9 | 44 7 | 45 0 | 15 0^*^ | 33 4 | 1,198 | 3 9 | 0 67 | 4 57 | 0 10 | 0 11 | 0 01 | 0 01
| 1 564 | 0 387 | 0 45 | 1 97 | 1 67 | 0 70 | 1 28 | 161 7 | 0 36 | 0 184 | 1 370 | 0 020 | 0 037 | 0 009 | 0 007
100 + 100 | 5 74 | 8 33^**^ | 13 9^**^ | 42 4^*^ | 51 0^**^ | 16 7^**^ | 32 9 | 1,397 | 4 6 | 0 70 | 4 78 | 0 07 | 0 16 | 0 02 | 0 01
| 1 583 | 0 392 | 0 62 | 1 62 | 1 13 | 0 41 | 0 51 | 270 2 | 0 77 | 0 372 | 1 334 | 0 031 | 0 065 | 0 007 | 0 017
200 + 100 | 5 07 | 7 64^**^ | 13 5^**^ | 41 1^**^ | 53 8^**^ | 17 6^**^ | 32 7 | 1,430 | 5 2 | 0 64 | 4 25 | 0 06 | 0 11 | 0 01 | 0 01
| 1 301 | 0 255 | 0 44 | 1 54 | 1 30 | 0 45 | 0 66 | 183 8 | 0 46 | 0 219 | 1 149 | 0 017 | 0 031 | 0 007 | 0 010
400 + 100 | 5 24 | 6 79^**^ | 12 3^**^ | 38 4^**^ | 56 6^**^ | 18 2^**^ | 32 2^**^ | 1,893^**^ | 5 8^c^ | 0 58 | 4 45 | 0 07 | 0 11 | 0 01 | 0 01
| 0 868 | 0 346 | 0 55 | 2 08 | 1 42 | 0 47 | 0 65 | 194 4 | 0 34 | 0 159 | 0 695 | 0 024 | 0 038 | 0 011 | 0 006
0 + 200 | 6 13 | 9 87 | 14 2^*^ | 42 8 | 43 4^**^ | 14 4^**^ | 33 2 | 1,307 | 3 6 | 0 89 | 5 01 | 0 09 | 0 12 | 0 02 | 0 01
| 1 686 | 0 330 | 0 60 | 1 60 | 0 55 | 0 29 | 0 50 | 108 9 | 0 31 | 0 242 | 1 435 | 0 037 | 0 053 | 0 013 | 0 008
100 + 200^e^ | 5 11 | 7 30^**^ | 12 2^**^ | 38 1^**^ | 52 3^**^ | 16 8^**^ | 32 1^**^ | 1,606^**^ | 5 4 | 0 62 | 4 32 | 0 08 | 0 08 | 0 01 | 0 01
| 1 167 | 0 514 | 0 68 | 1 88 | 1 83 | 0 51 | 0 48 | 277 2 | 0 96 | 0 222 | 0 978 | 0 021 | 0 025 | 0 006 | 0 008
200 + 200 | 5 50 | 5 43^**^ | 9 5^**^ | 29 1^**^ | 53 4^**^ | 17 5^**^ | 32 9 | 2,308^**^ | 5 1 | 0 71 | 4 58 | 0 08 | 0 10 | 0 01 | 0 01
| 1 593 | 0 914 | 1 63 | 5 59 | 2 31 | 0 47 | 1 17 | 508 5 | 1 42 | 0 279 | 1 309 | 0 045 | 0 031 | 0 008 | 0 006
400 + 200^k^ | 4 58 | 3 27^**^ | 5 3^**^ | 15 5^**^ | 47 2 | 16 2 | 34 4 | 3,144^**^ | 2 2^**^ | 0 75 | 3 67 | 0 07 | 0 08 | 0 01 | 0 00
| 1 420 | 0 566 | 1 16 | 3 34 | 2 25 | 0 75 | 0 15 | 397 8 | 0 47 | 0 180 | 1 272 | 0 032 | 0 040 | 0 006 | 0 000
0 + 400 | 5 37 | 8 84^**^ | 12 3^**^ | 38 3^**^ | 43 3^**^ | 13 9^**^ | 32 1^**^ | 1,458 | 4 5 | 0 89 | 4 27 | 0 11 | 0 09 | 0 01 | 0 01
| 1 297 | 0 583 | 0 72 | 2 56 | 1 09 | 0 41 | 0 64 | 140 3 | 1 26 | 0 216 | 1 082 | 0 032 | 0 076 | 0 007 | 0 007
100 + 400^j^ | 3 91 | 3 24^**^ | 5 3^**^ | 15 6^**^ | 48 0 | 16 2 | 33 9 | 2,791^**^ | 1 9^**^ | 0 56 | 3 28 | 0 05 | 0 02 | 0 01 | 0 01
| 0 919 | 0 594 | 1 13 | 3 54 | 2 19 | 0 42 | 0 64 | 198 7 | 0 00 | 0 057 | 0 940 | 0 021 | 0 000 | 0 007 | 0 007
200 + 400^l^ | 0 74 | 1 10^**^ | 1 8^**^ | 5 0^**^ | 45 3 | 16 0 | 35 4 | 445 | 0 5^**^ | 0 08 | 0 64 | 0 00 | 0 02 | 0 00 | 0 00
400 + 400^g^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.001

a Daily gavage doses of AZT + rifampicin (mg/kg per day) For each parameter, the mean is presented above the standard deviation, n=10, unless otherwise noted

b WBC counts corrected for reticulocyte (nucleated erythrocyte) counts greater than 10 per 100 WBCs

c n=9

d Large unstained cells

e n=8

f n=7

g No data were available due to 100% mortality in this group

h n=6

i n=4

j n=2

k n=3

l n=1, standard deviation not calculated due to high mortality

TABLE A2 Hematology Data for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | WBC^b^ (10^3^/mm^3^) | RBC (10^6^/mm^3^) | Hgb (g/dL) | Hct (%) | MCV (fL) | MCH (Pg) | MCHC (g/dL) | Platelets (10^3^/mm^3^) | Reticulocytes (10^5^/mm^3^) | Neutrophils (10^3^/mm^3^) | Lymphocytes (10^3^/mm^3^) | Monocytes (10^3^/mm^3^) | Eosinophils (10^3^/mm^3^) | Basophils (10^3^/mm^3^) | LUC^d^ (10^3^/mm^3^)
Day 4
0 + 0 | 5 99 | 9 73 | 15 3 | 47 3 | 48 6 | 15 8 | 32 4 | 1,124 | 3 1^c^ | 0 56 | 5 07 | 0 12 | 0 19 | 0 02 | 0 02
| 1 488 | 0 440 | 0 42 | 1 56 | 0 98 | 0 44 | 0 55 | 74 4 | 0 49 | 0 150 | 1 329 | 0 030 | 0 107 | 0 009 | 0 007
100 + 0 | 6 39 | 9 11^**^ | 14 5^*^ | 44 5^**^ | 48 8 | 15 9 | 32 6 | 1,048 | 1 3^**^ | 0 55 | 5 49 | 0 17 | 0 14 | 0 02 | 0 02
| 0 991 | 0 211 | 0 61 | 1 76 | 1 13 | 0 45 | 0 43 | 153 0 | 0 32 | 0 178 | 0 854 | 0 065 | 0 049 | 0 004 | 0 007
200 + 0 | 5 34 | 9 30^*^ | 14 7 | 45 4 | 48 8 | 15 8 | 32 4 | 1,206 | 1 5^**^,^c^ | 0 42 | 4 64 | 0 10 | 0 15 | 0 02 | 0 02
| 1 123 | 0 236 | 0 47 | 1 48 | 1 19 | 0 38 | 0 44 | 63 9 | 0 21 | 0 115 | 1 011 | 0 033 | 0 044 | 0 007 | 0 008
400 + 0 | 5 88 | 9 38 | 14 9 | 45 6 | 48 6 | 15 9 | 32 8 | 1,159 | 1 4^**^ | 0 44 | 5 11 | 0 13 | 0 16 | 0 02 | 0 02
| 1 210 | 0 274 | 0 40 | 1 36 | 1 11 | 0 37 | 0 78 | 69 1 | 0 50 | 0 089 | 1 072 | 0 042 | 0 064 | 0 010 | 0 009
0 + 100 | 6 17 | 9 34 | 14 7 | 45 4 | 48 6 | 15 8 | 32 5 | 1,128 | 1 8^**^ | 0 69 | 5 10 | 0 17 | 0 18 | 0 02 | 0 02
| 1 303 | 0 103 | 0 39 | 1 34 | 1 32 | 0 43 | 0 28 | 102 0 | 0 78 | 0 209 | 1 163 | 0 050 | 0 062 | 0 009 | 0 006
100 + 100 | 6 37 | 9 32 | 14 8 | 45 7 | 49 0 | 15 9 | 32 5 | 1,164 | 1 0^**^ | 0 52 | 5 51 | 0 13 | 0 18 | 0 02 | 0 02
| 1 429 | 0 306 | 0 46 | 1 46 | 1 00 | 0 35 | 0 48 | 92 9 | 0 29 | 0 160 | 1 234 | 0 059 | 0 061 | 0 005 | 0 005
200 + 100 | 6 01 | 9 11^**^ | 14 4^**^ | 44 4^**^ | 48 7 | 15 8 | 32 4 | 1,150 | 0 8^**^ | 0 46 | 5 23 | 0 12 | 0 17 | 0 02 | 0 02
| 1 527 | 0 217 | 0 50 | 1 58 | 1 16 | 0 38 | 0 50 | 60 1 | 0 29 | 0 187 | 1 356 | 0 034 | 0 065 | 0 005 | 0 007
400 + 100 | 6 83 | 9 10^**^ | 14 5^*^ | 44 1^**^ | 48 4 | 15 9 | 32 8 | 1,163 | 0 6^**^,^c^ | 0 66 | 5 82 | 0 12 | 0 17 | 0 02 | 0 03
| 1 750 | 0 307 | 0 49 | 2 00 | 1 30 | 0 37 | 0 77 | 63 0 | 0 10 | 0 190 | 1 571 | 0 034 | 0 062 | 0 007 | 0 012
0 + 200 | 7 26 | 9 37 | 14 8 | 45 6 | 48 6 | 15 8 | 32 6 | 1,258^*^ | 1 1^**^ | 0 77 | 6 05 | 0 16 | 0 23 | 0 02 | 0 02
| 1 526 | 0 426 | 0 77 | 2 21 | 1 58 | 0 43 | 0 44 | 107 8 | 0 45 | 0 122 | 1 416 | 0 022 | 0 101 | 0 014 | 0 012
100 + 200 | 6 17 | 9 33 | 14 8 | 45 5 | 48 7 | 15 9 | 32 5 | 1,172 | 0 7^**^ | 0 58 | 5 28 | 0 12 | 0 17 | 0 02 | 0 02
| 1 275 | 0 240 | 0 44 | 1 13 | 1 02 | 0 37 | 0 46 | 90 9 | 0 16 | 0 198 | 1 041 | 0 044 | 0 057 | 0 007 | 0 005
200 + 200 | 6 03 | 9 12^**^ | 14 4^*^ | 44 2^**^ | 48 4 | 15 8 | 32 7 | 1,140 | 0 6^**^ | 0 67 | 5 03 | 0 14 | 0 15 | 0 02 | 0 02
| 1 411 | 0 257 | 0 62 | 1 99 | 1 25 | 0 44 | 0 55 | 59 4 | 0 15 | 0 244 | 1 234 | 0 040 | 0 067 | 0 009 | 0 005
400 + 200 | 5 89 | 9 08^**^ | 14 4^*^ | 44 0^**^ | 48 5 | 15 9 | 32 8 | 1,137 | 0 5^**^ | 0 64 | 4 96 | 0 11 | 0 14 | 0 01 | 0 02
| 0 923 | 0 273 | 0 44 | 1 19 | 1 13 | 0 38 | 0 42 | 81 6 | 0 23 | 0 248 | 0 725 | 0 034 | 0 058 | 0 005 | 0 008
0 + 400 | 6 08 | 9 45 | 15 1 | 46 1 | 48 7 | 16 0 | 32 7 | 1,170 | 0 7^**^ | 0 79 | 4 98 | 0 12 | 0 14 | 0 02 | 0 02
| 1 603 | 0 360 | 0 58 | 1 90 | 1 33 | 0 36 | 0 40 | 194 2 | 0 17 | 0 241 | 1 474 | 0 039 | 0 059 | 0 008 | 0 010
100 + 400^c^ | 6 03 | 9 50 | 15 0 | 45 9 | 48 3 | 15 8 | 32 7 | 1,218 | 0 7^**^ | 0 76 | 4 92 | 0 12 | 0 19 | 0 02 | 0 02
| 1 390 | 0 164 | 0 41 | 1 12 | 1 44 | 0 47 | 0 58 | 88 1 | 0 24 | 0 287 | 1 109 | 0 055 | 0 118 | 0 009 | 0 008
200 + 400 | 5 88 | 9 18^**^ | 14 6 | 44 6^*^ | 48 6 | 16 0 | 32 9 | 1,202 | 0 5^**^ | 0 54 | 5 03 | 0 11 | 0 17 | 0 02 | 0 02
| 1 181 | 0 252 | 0 42 | 1 26 | 1 08 | 0 37 | 0 44 | 79 0 | 0 10 | 0 125 | 1 018 | 0 031 | 0 060 | 0 011 | 0 009
400 + 400 | 3 90 | 10 12 | 16 0 | 47 8 | 47 2 | 15 8 | 33 4 | 1,318^**^ | 0 7^**^ | 0 77 | 2 93^**^ | 0 10 | 0 08 | 0 01 | 0 01^c^
| 1 743 | 0 759 | 1 36 | 3 88 | 1 32 | 0 43 | 0 56 | 96 1 | 0 17 | 0 370 | 1 731 | 0 053 | 0 068 | 0 010 | 0 008
Day 30
0 + 0^c^ | 6 47 | 9 25 | 14 9 | 44 9 | 48 5 | 16 1 | 33 2 | 1,129 | 3 4^g^ | 0 60 | 5 53 | 0 15 | 0 17 | 0 02 | 0 02
| 1 090 | 0 125 | 0 23 | 0 85 | 0 82 | 0 31 | 0 59 | 95 9 | 0 42 | 0 148 | 0 979 | 0 046 | 0 089 | 0 009 | 0 007
100 + 0 | 6 60 | 8 28 | 14 5 | 44 2 | 53 4^**^ | 17 5^**^ | 32 8 | 1,282 | 4 4 | 0 65 | 5 59 | 0 14 | 0 19 | 0 02 | 0 02
| 1 045 | 0 367 | 0 47 | 1 72 | 0 69 | 0 43 | 0 55 | 108 8 | 0 53 | 0 203 | 0 832 | 0 043 | 0 082 | 0 007 | 0 005
200 + 0 | 5 43 | 7 97^**^ | 14 1 | 43 1 | 54 1^**^ | 17 6^**^ | 32 6 | 1,412^*^ | 5 6 | 0 69 | 4 48 | 0 13 | 0 10 | 0 01 | 0 01
| 1 632 | 0 223 | 0 45 | 1 25 | 0 77 | 0 24 | 0 32 | 45 5 | 0 65 | 0 298 | 1 372 | 0 054 | 0 050 | 0 007 | 0 005
400 + 0 | 5 47 | 8 04^*^ | 14 4 | 44 8 | 55 7^**^ | 17 9^**^ | 32 1 | 1,404 | 5 4 | 0 55 | 4 64 | 0 11 | 0 14 | 0 01 | 0 02
| 1 217 | 0 171 | 0 28 | 0 99 | 0 97 | 0 31 | 0 44 | 121 8 | 0 68 | 0 168 | 1 002 | 0 022 | 0 081 | 0 005 | 0 007
0 + 100 | 6 45 | 9 54 | 15 0 | 46 0 | 48 3 | 15 8 | 32 7 | 1,221 | 3 9 | 0 62 | 5 50 | 0 15 | 0 15 | 0 02 | 0 02
| 0 864 | 0 421 | 0 46 | 1 74 | 0 79 | 0 41 | 0 53 | 127 8 | 0 51 | 0 159 | 0 741 | 0 031 | 0 047 | 0 005 | 0 011
100 + 100^e^ | 6 48 | 8 11^*^ | 14 1 | 43 3 | 53 5^**^ | 17 4^**^ | 32 6 | 1,376 | 4 4^h^ | 0 71 | 5 46 | 0 14 | 0 13 | 0 02 | 0 02
| 1 044 | 0 336 | 0 64 | 1 65 | 0 53 | 0 16 | 0 55 | 113 6 | 0 64 | 0 247 | 0 894 | 0 036 | 0 034 | 0 006 | 0 011
200 + 100^c^ | 4 73^*^ | 7 33^**^ | 13 0 | 40 9 | 55 8^**^ | 17 8^**^ | 31 8 | 1,469^**^ | 5 2^e^ | 0 51 | 3 99^*^ | 0 10 | 0 10 | 0 01 | 0 01
| 0 696 | 0 245 | 0 45 | 1 09 | 0 88 | 0 35 | 0 53 | 131 3 | 0 80 | 0 117 | 0 613 | 0 032 | 0 031 | 0 005 | 0 007
400 + 100 | 5 68 | 4 79^**^ | 8 7^**^ | 27 6^**^ | 54 4^**^ | 17 7^**^ | 33 0 | 1,929^**^ | 11 3^**^,^c^ | 0 87^*^ | 4 57 | 0 08^**^ | 0 12 | 0 01 | 0 02
| 1 581 | 2 330 | 4 59 | 15 60 | 8 74 | 1 55 | 2 83 | 326 4 | 7 49 | 0 340 | 1 218 | 0 051 | 0 109 | 0 010 | 0 009
0 + 200 | 7 27 | 9 32 | 14 5 | 44 2 | 47 4 | 15 6 | 32 9 | 1,153 | 3 8^e^ | 0 93^**^ | 5 97 | 0 20^*^ | 0 13 | 0 02 | 0 02
| 1 694 | 0 390 | 0 56 | 1 82 | 0 66 | 0 29 | 0 57 | 177 5 | 0 97 | 0 220 | 1 478 | 0 050 | 0 052 | 0 008 | 0 008
100 + 200 | 6 40 | 6 89^**^ | 11 7^**^ | 36 6^**^ | 53 1^**^ | 17 0^*^ | 31 9 | 1,762^**^ | 6 0^c^ | 0 79 | 5 31 | 0 14 | 0 12 | 0 02 | 0 02
| 1 210 | 0 388 | 0 72 | 2 42 | 1 06 | 0 30 | 0 57 | 139 9 | 1 24 | 0 249 | 0 976 | 0 045 | 0 063 | 0 007 | 0 006
200 + 200 | 4 92^*^ | 2 91^**^ | 4 9^**^ | 14 9^**^ | 48 6 | 16 5 | 34 2 | 2,036^**^ | 4 3^c^ | 0 51 | 4 24 | 0 07^**^ | 0 06^**^ | 0 01 | 0 02
| 1 253 | 1 578 | 2 95 | 10 09 | 6 32 | 0 84 | 2 76 | 292 9 | 4 13 | 0 223 | 1 209 | 0 052 | 0 030 | 0 007 | 0 020
400 + 200 | 4 26^**^ | 1 42^**^ | 2 2^**^ | 6 1^**^ | 42 8^**^ | 15 5 | 36 3^**^ | 1,577^**^ | 0 5 | 0 30^*^ | 3 90^**^ | 0 02^**^ | 0 02^**^ | 0 01 | 0 02
| 0 814 | 0 095 | 0 16 | 0 41 | 1 05 | 0 44 | 1 01 | 161 8 | 0 09 | 0 100 | 0 725 | 0 009 | 0 008 | 0 005 | 0 012
0 + 400 | 7 56 | 9 11 | 13 8 | 41 7 | 45 8 | 15 1^**^ | 33 1 | 1,381 | 2 3^c^ | 1 11^**^ | 6 11 | 0 17 | 0 14 | 0 02 | 0 02
| 0 743 | 0 185 | 0 36 | 1 02 | 0 73 | 0 30 | 0 83 | 172 4 | 0 73 | 0 258 | 0 880 | 0 050 | 0 080 | 0 012 | 0 006
100 + 400 | 3 81^**^ | 1 85^**^ | 2 9^**^ | 7 8^**^ | 42 3^**^ | 15 5 | 36 7^**^ | 1,415^*^ | 0 5 | 0 34 | 3 41^**^ | 0 03^**^ | 0 03^**^ | 0 01 | 0 01
| 0 593 | 0 350 | 0 48 | 1 53 | 0 73 | 0 51 | 1 24 | 168 8 | 0 20 | 0 143 | 0 484 | 0 013 | 0 018 | 0 003 | 0 007
200 + 400^c^ | 3 67^**^ | 1 58^**^ | 2 4^**^ | 6 7^**^ | 42 4^**^ | 15 6 | 36 8^**^ | 1,327 | 0 5^e^ | 0 26^**^ | 3 34^**^ | 0 02^**^ | 0 02^**^ | 0 01^*^ | 0 01
| 1 442 | 0 378 | 0 57 | 1 66 | 1 02 | 0 21 | 1 26 | 523 7 | 0 16 | 0 130 | 1 341 | 0 009 | 0 013 | 0 005 | 0 007
400 + 400^f^ | 1 29^**^ | 1 21^**^ | 1 8^**^ | 4 8^**^ | 39 7^**^ | 15 3 | 38 7^**^ | 307^**^ | 0 1 | 0 16^*^ | 1 08^**^ | 0 02^**^ | 0 03^**^ | 0 01 | 0 00
| 0 826 | 0 271 | 0 40 | 1 29 | 2 14 | 0 46 | 3 29 | 238 0 | 0 06 | 0 076 | 0 789 | 0 006 | 0 006 | 0 006 | 0 006
Day 60
0 + 0^c^ | 4 16 | 10 24 | 16 4 | 48 4 | 47 3 | 16 0 | 33 9 | 1,035 | 3 5^e^ | 0 40 | 3 58 | 0 09 | 0 08 | 0 01 | 0 01
| 1 384 | 0 500 | 0 76 | 2 54 | 1 09 | 0 20 | 0 72 | 194 0 | 0 49 | 0 212 | 1 147 | 0 047 | 0 044 | 0 006 | 0 009
100 + 0 | 3 69 | 8 18^**^ | 14 6 | 43 7 | 53 4^**^ | 17 8^**^ | 33 4 | 1,117 | 3 5 | 0 39 | 3 11 | 0 08 | 0 10 | 0 01 | 0 01
| 1 297 | 0 241 | 0 46 | 0 68 | 1 08 | 0 28 | 0 71 | 120 7 | 0 51 | 0 164 | 1 096 | 0 037 | 0 021 | 0 007 | 0 006
200 + 0 | 3 41 | 7 76^**^ | 14 4 | 43 4 | 55 9^**^ | 18 5^**^ | 33 1 | 1,128 | 4 3 | 0 39 | 2 85 | 0 07 | 0 09 | 0 01 | 0 01^e^
| 1 096 | 0 386 | 0 65 | 2 17 | 1 60 | 0 23 | 0 76 | 139 9 | 0 86 | 0 146 | 0 964 | 0 024 | 0 056 | 0 005 | 0 009
400 + 0 | 3 49 | 7 42^**^ | 14 1 | 42 9 | 57 8^**^ | 19 0^**^ | 33 0 | 1,178 | 4 4 | 0 33 | 2 96 | 0 07 | 0 12 | 0 01 | 0 01
| 0 920 | 0 279 | 0 43 | 1 68 | 0 72 | 0 29 | 0 76 | 125 3 | 0 62 | 0 126 | 0 738 | 0 026 | 0 068 | 0 006 | 0 005
0 + 100 | 3 67 | 9 15 | 14 6 | 43 7 | 47 8 | 15 9 | 33 3 | 1,054 | 3 0 | 0 38 | 3 11 | 0 09 | 0 08 | 0 01 | 0 01
| 0 810 | 0 482 | 0 71 | 1 84 | 0 98 | 0 20 | 0 71 | 179 9 | 0 57 | 0 134 | 0 633 | 0 028 | 0 047 | 0 006 | 0 005
100 + 100 | 3 63 | 7 53^**^ | 13 5^*^ | 41 8 | 55 6^**^ | 18 0^**^ | 32 4 | 1,235 | 4 6 | 0 42 | 3 02 | 0 08 | 0 09 | 0 01 | 0 01
| 0 601 | 0 259 | 0 36 | 1 60 | 1 16 | 0 28 | 0 88 | 139 2 | 1 18 | 0 109 | 0 505 | 0 037 | 0 042 | 0 003 | 0 000
200 + 100 | 3 73 | 7 22^**^ | 13 4^*^ | 41 7 | 57 7^**^ | 18 6^**^ | 32 3 | 1,247 | 4 4 | 0 46 | 3 10 | 0 07 | 0 08 | 0 01 | 0 01
| 0 879 | 0 314 | 0 38 | 1 60 | 1 13 | 0 35 | 0 51 | 151 0 | 0 77 | 0 175 | 0 700 | 0 026 | 0 028 | 0 004 | 0 004
400 + 100^i^ | 1 96 | 4 24^**^ | 8 1^**^ | 25 1^**^ | 54 7^**^ | 18 6^**^ | 34 5 | 949 | 3 4 | 0 31 | 1 56 | 0 05 | 0 04 | 0 00 | 0 01^l^
| 1 354 | 3 206 | 6 14 | 19 74 | 7 70 | 0 83 | 3 83 | 476 6 | 2 80 | 0 302 | 1 001 | 0 060 | 0 040 | 0 000 | 0 007
0 + 200 | 4 67 | 9 39 | 14 5 | 43 0 | 45 9 | 15 4^**^ | 33 6 | 1,156 | 2 7 | 0 52 | 3 97 | 0 09 | 0 08 | 0 01 | 0 01
| 1 256 | 0 168 | 0 31 | 0 91 | 0 95 | 0 16 | 0 56 | 128 3 | 0 53 | 0 207 | 1 092 | 0 030 | 0 035 | 0 007 | 0 005
100 + 200 | 3 54 | 5 67^**^ | 10 2^**^ | 32 0^**^ | 54 3^**^ | 17 7^**^ | 32 8 | 1,418 | 4 9 | 0 54 | 2 85 | 0 07 | 0 08 | 0 01 | 0 01
| 1 191 | 2 364 | 4 34 | 14 18 | 5 99 | 0 87 | 2 53 | 450 6 | 2 16 | 0 185 | 0 940 | 0 028 | 0 086 | 0 008 | 0 004
200 + 200^j^ | 4 49 | 6 72^*^ | 12 5 | 41 2 | 61 3^**^ | 18 6^**^ | 30 4 | 1,493 | 5 5 | 0 60 | 3 76 | 0 06 | 0 04 | 0 01 | 0 01
400 + 200^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
0 + 400 | 4 37 | 9 34 | 13 7^*^ | 41 4 | 44 4 | 14 6^**^ | 33 0 | 1,231 | 1 9^*^ | 0 50 | 3 71 | 0 08 | 0 07 | 0 01 | 0 01
| 1 062 | 0 548 | 0 70 | 2 37 | 1 11 | 0 18 | 0 69 | 152 6 | 0 42 | 0 148 | 0 909 | 0 027 | 0 044 | 0 007 | 0 007
100 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
200 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
400 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
Days 92 to 95
0 + 0 | 3 65 | 9 85 | 15 6 | 46 4 | 47 1 | 15 9 | 33 7 | 975 | 3 7 | 0 45 | 3 06 | 0 07 | 0 06 | 0 01 | 0 01
| 0 951 | 0 293 | 0 62 | 1 72 | 1 15 | 0 29 | 0 46 | 178 7 | 0 65 | 0 186 | 0 762 | 0 031 | 0 015 | 0 006 | 0 005
100 + 0 | 3 33 | 7 95^**^ | 14 5 | 43 3 | 54 4^**^ | 18 2^**^ | 33 5 | 1,027 | 3 9 | 0 29 | 2 91 | 0 04 | 0 07 | 0 01 | 0 00
| 0 712 | 0 270 | 0 67 | 1 82 | 1 14 | 0 61 | 0 92 | 181 5 | 0 81 | 0 097 | 0 675 | 0 008 | 0 022 | 0 006 | 0 003
200 + 0 | 3 65 | 7 40^**^ | 13 9 | 42 8 | 57 9^**^ | 18 8^**^ | 32 4^*^ | 1,331^*^ | 5 2 | 0 34 | 3 14 | 0 06 | 0 09 | 0 01 | 0 01
| 0 995 | 0 375 | 0 63 | 1 90 | 0 94 | 0 34 | 0 55 | 183 4 | 0 68 | 0 117 | 0 831 | 0 028 | 0 045 | 0 006 | 0 007
400 + 0^c^ | 3 21 | 6 88^**^ | 13 3^**^ | 41 0 | 59 6^**^ | 19 3^**^ | 32 4^*^ | 1,319^*^ | 5 4^*^ | 0 23^*^ | 2 85 | 0 05 | 0 06 | 0 01 | 0 00
| 0 902 | 0 413 | 0 87 | 2 42 | 1 65 | 0 36 | 0 78 | 301 8 | 0 67 | 0 100 | 0 784 | 0 025 | 0 025 | 0 004 | 0 005
0 + 100 | 3 82 | 9 31 | 14 4 | 43 4 | 46 6 | 15 5 | 33 1 | 1,057 | 3 6 | 0 42 | 3 27 | 0 06 | 0 07 | 0 01 | 0 00
| 0 808 | 0 334 | 0 62 | 1 94 | 1 15 | 0 36 | 0 61 | 156 0 | 0 80 | 0 166 | 0 678 | 0 019 | 0 028 | 0 000 | 0 005
100 + 100^c^ | 3 33 | 6 73^**^ | 12 5^**^ | 38 5^**^ | 57 2^**^ | 18 6^**^ | 32 6^*^ | 1,496^**^ | 4 6 | 0 32 | 2 87 | 0 05 | 0 09 | 0 01 | 0 00
| 0 999 | 0 248 | 0 53 | 1 32 | 1 82 | 0 61 | 0 87 | 140 9 | 0 70 | 0 169 | 0 793 | 0 025 | 0 052 | 0 008 | 0 005
200 + 100 | 3 48 | 6 25^**^ | 12 0^**^ | 38 1^**^ | 61 0^**^ | 19 3^**^ | 31 5^**^ | 1,627 | 6 7^**^ | 0 39 | 2 95 | 0 05 | 0 08 | 0 01 | 0 01
| 1 072 | 0 329 | 0 65 | 2 29 | 2 07 | 0 40 | 0 73 | 223 1 | 0 89 | 0 165 | 0 885 | 0 035 | 0 042 | 0 003 | 0 005
400 + 100^g^ | 3 00 | 4 09^**^ | 8 0^**^ | 25 0^**^ | 60 0^**^ | 19 4^**^ | 32 3^*^ | 2,088^**^ | 4 4 | 0 35 | 2 56 | 0 05 | 0 04 | 0 00 | 0 00
| 1 030 | 1 673 | 3 33 | 10 68 | 3 93 | 0 99 | 0 82 | 336 4 | 1 77 | 0 156 | 0 854 | 0 035 | 0 020 | 0 005 | 0 005
0 + 200 | 3 90 | 9 21 | 13 9 | 42 0 | 45 6 | 15 1^**^ | 33 0 | 1,242 | 4 6^c^ | 0 48 | 3 30 | 0 05 | 0 06 | 0 01 | 0 01^c^
| 0 731 | 0 413 | 0 58 | 2 01 | 0 93 | 0 28 | 0 54 | 160 4 | 2 02 | 0 217 | 0 661 | 0 020 | 0 037 | 0 007 | 0 005
100 + 200 | 2 84 | 3 42^**^ | 6 3^**^ | 19 6^**^ | 55 4^**^ | 18 3^**^ | 33 1 | 2,209^**^ | 3 3 | 0 32 | 2 39 | 0 06 | 0 05 | 0 00 | 0 00
| 0 980 | 1 758 | 3 36 | 11 05 | 4 58 | 0 67 | 1 85 | 471 5 | 1 64 | 0 168 | 0 840 | 0 058 | 0 034 | 0 005 | 0 004
200 + 200^m^ | 2 25 | 1 56^**^ | 2 5^**^ | 7 3^**^ | 46 3 | 16 2 | 35 1 | 2,020^**^ | 0 9^**^ | 0 26 | 1 96 | 0 01 | 0 02 | 0 00 | 0 00
| 1 095 | 0 326 | 0 59 | 1 72 | 1 68 | 0 45 | 0 70 | 560 9 | 0 28 | 0 172 | 0 923 | 0 010 | 0 010 | 0 000 | 0 005
400 + 200^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
0 + 400 | 3 87 | 8 77^*^ | 12 5^**^ | 38 5^**^ | 43 9^*^ | 14 3^**^ | 32 5^*^ | 1,294 | 4 4 | 0 63 | 3 12 | 0 06 | 0 05 | 0 01 | 0 01^c^
| 1 182 | 0 408 | 0 65 | 2 48 | 1 54 | 0 33 | 0 69 | 98 6 | 1 82 | 0 168 | 1 092 | 0 029 | 0 031 | 0 009 | 0 005
100 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
200 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —
400 + 400^k^ | — | — | — | — | — | — | — | — | — | — | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day) For each parameter, the mean is presented above the standard deviation, n=10, unless otherwise noted

b WBC counts corrected for reticulocyte (nucleated erythrocyte) counts greater than 10 per 100 WBCs

c n=9

d Large unstained cells

e n=8

f n=3

g n=7

h n=6

i n=5

j n=1, standard deviation not calculated due to high mortality

k No data were available due to 100% mortality in this group

l n=2

m n=4

TABLE A3 Clinical Chemistry Data for Male Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | ALP (U/L) | ALT (U/L) | AST (U/L) | SDH (U/L) | Bile Acids (μmol/L)
Day 4
0 + 0 | 154 | 31^b^ | 65^c^ | —^d^ | —
| 20 2 | 5 6
100 + 0 | 150 | 31^b^ | 103^e^ | 42^c^ | 38^c^
| 24 5 | 6 1 | 49 4
200 + 0 | 142^f^ | 32^e^ | 96^c^ | 27^c^ | —
| 23 3 | 8 1
400 + 0 | 157^f^ | 27^g^ | 61^c^ | — | —
| 13 5 | 6 0
0 + 100 | 156^f^ | 43 | 80^c^ | 19^c^ | —
| 14 7 | 23 4
100 + 100 | 152 | 30^h^ | 64^c^ | — | —
| 20 4 | 2 4
200 + 100 | 150 | 32 | 72^i^ | 43^c^ | —
| 9 7 | 4 6 | 5 7
400 + 100 | 158^j^ | 28^b^ | 71^c^ | — | —
| 10 8 | 3 3
0 + 200 | 165^f^ | 33^g^ | 70^i^ | — | —
| 6 4 | 1 0 | 1 4
100 + 200 | 174^j^ | 39 | 77^i^ | 30^c^ | 29^c^
| 14 8 | 5 8 | 2 1
200 + 200 | 169^f^ | 36^f^ | 85^h^ | 33^c^ | 34^i^
| 22 2 | 3 6 | 19 4 | | 1 4
400 + 200 | 157 | 34^k^ | 82^c^ | — | —
| 18 2 | 4 8
0 + 400 | 154^f^ | 40^k^ | 87^i^ | — | —
| 22 6 | 2 8 | 12 0
100 + 400 | 164^f^ | 44^h^ | 80^c^ | — | —
| 21 3 | 6 6
200 + 400 | 166^b^ | 38^h^ | 81^i^ | — | —
| 17 7 | 8 0 | 28 3
400 + 400 | 166^b^ | 34^e^ | 57^c^ | — | —
| 15 2 | 3 6
Day 30
0 + 0 | 89 | 32 | 77^g^ | — | 10^c^
| 11.7 | 6.4 | 17.8
100 + 0 | 94 | 35 | 67^b^ | 34^i^ | 12^i^
| 7.5 | 12.6 | 13.1 | 8.5 | 1.4
200 + 0 | 92^b^ | 29^b^ | 73^h^
| 9.9 | 4.0 | 13.4 | — | —
400 + 0 | 94^j^ | 29^j^ | 64^f^ | 20^c^ | 5^i^
| 14.5 | 11.0 | 12.5 | | 3.5
0 + 100 | 116^**^ | 32 | 76^h^ | 36^i^ | 10^c^
| 8.0 | 5.2 | 16.2 | 6.4
100 + 100 | 102 | 32 | 74^b^ | 46^c^ | 20^c^
| 7.5 | 15.1 | 20.4
200 + 100 | 105 | 31 | 53^g^ | — | 15^c^
| 12.1 | 8.5 | 13.6
400 + 100 | 97 | 28 | 68^b^ | 37^i^ | 8^c^
| 12.6 | 5.3 | 29.3 | 4.9
0 + 200 | 111^*^,^b^ | 32^b^ | 71^g^ | 26^e^ | 26^i^
| 8.9 | 4.8 | 10.1 | 7.5 | 6.4
100 + 200 | 116^*^,^f^ | 33^f^ | 71^g^ | 36^i^ | 51^c^
| 15.9 | 4.7 | 10.0 | 7.1
200 + 200 | 112^*^,^b^ | 45^b^ | 73^k^ | — | 12^i^
| 7.5 | 33.7 | 11.5 | | 4.9
400 + 200 | 122^*^,^f^ | 29^f^ | 67^f^ | 32^e^ | 63^e^
| 18.2 | 6.8 | 12.1 | 19.5 | 40.8
0 + 400 | 178^*^,^b^ | 46^b^ | 82^b^ | 55^c^ | 72^i^
| 29.4 | 9.1 | 17.9 | | 21.2
100 + 400 | 155^*^,^b^ | 42^b^ | 83^b^ | 35^k^ | 144^c^
| 9.8 | 5.4 | 24.7 | 5.4
200 + 400 | 128^**^,^b^ | 34^b^ | 68^b^ | 38^g^ | 116^e^
| 16.7 | 8.7 | 14.1 | 6.6 | 33.2
400 + 400^l^ | — | — | — | — | —
Day 60
0 + 0 | 91 | 28 | 63^f^ | 23^c^ | 22^k^
| 10 8 | 9 0 | 20 8 | | 1 0
100 + 0 | 83 | 30 | 63 | 36^k^ | 41^h^
| 6 4 | 7 3 | 13 1 | 1 9 | 30 5
200 + 0 | 88 | 32 | 69^f^ | 38^i^ | 40^h^
| 9 1 | 9 1 | 13 5 | 0 7 | 28 8
400 + 0 | 81^j^ | 26^j^ | 57^j^ | 32^h^ | 23^h^
| 5 6 | 5 5 | 14 8 | 7 0 | 7 5
0 + 100 | 122^**^ | 30 | 65 | 32^k^ | 24^k^
| 9 8 | 2 9 | 14 1 | 7 4 | 4 2
100 + 100 | 123^**^,^j^ | 29^j^ | 63 | 36^c^ | 36^h^
| 11 8 | 2 9 | 25 0 | | 23 3
200 + 100 | 127^**^,^j^ | 36^j^ | 73^j^ | 36^e^ | 27^h^
| 8 1 | 7 4 | 19 8 | 6 1 | 3 3
400 + 100 | 122^**^ | 27 | 58 | 36^h^ | 27^h^
| 10 2 | 5 3 | 7 5 | 6 1 | 5 4
0 + 200 | 170^**^ | 54 | 74^f^ | 38^h^ | 30^g^
| 11 8 | 13 7 | 16 1 | 1 8 | 3 5
100 + 200 | 174^**^,^f^ | 86^*^,^f^ | 97^f^ | — | 38^k^
| 8 9 | 35 8 | 23 1 | | 10 7
200 + 200 | 144^**^,^b^ | 36^b^ | 73^b^ | 42^e^ | 45^b^
| 13 0 | 6 9 | 13 8 | 7 9 | 7 9
400 + 200 | 157^**^,^k^ | 44^k^ | 83^k^ | 35^i^ | 37^i^
| 6 4 | 7 9 | 31 9 | 9 2 | 4 9
0 + 400 | 239^**^,^f^ | 208^**^,^f^ | 157^**^,^f^ | 42^c^ | 35^i^
| 15 7 | 147 9 | 109 3 | | 4 9
100 + 400 | 252^**^,^i^ | 143^**^,^i^ | 100^i^ | — | 85^c^
| 4 9 | 3 5 | 15 6
200 + 400^l^ | — | — | — | — | —
400 + 400^l^ | — | — | — | — | —
Days 92 to 95
0 + 0 | 80 | 22 | 67^b^ | 27^c^ | 30^c^
| 17 4 | 5 6 | 15 8
100 + 0 | 78^j^ | 22^j^ | 78^j^ | 39^e^ | 23^i^
| 17 1 | 7 2 | 21 6 | 10 5 | 4 9
200 + 0 | 74^f^ | 17^f^ | 68^g^ | 22^c^ | 20^c^
| 10 1 | 7 2 | 16 5
400 + 0 | 72^j^ | 22^j^ | 75^f^ | 39^k^ | 31^g^
| 15 0 | 7 2 | 22 1 | 11 6 | 18 6
0 + 100 | 135^**^,^f^ | 26^f^ | 70^b^ | 28^i^ | 56^i^
| 15 1 | 4 3 | 17 0 | 2 8 | 49 5
100 + 100 | 128^**^ | 30 | 75^f^ | 36^e^ | 27^k^
| 8 9 | 6 8 | 13 0 | 5 5 | 7 2
200 + 100 | 140^**^ | 27 | 69^b^ | 30^c^ | 32^h^
| 11 3 | 4 8 | 16 4 | | 12 5
400 + 100 | 139^**^ | 24 | 98^b^ | 37^e^ | 29^h^
| 10 4 | 4 6 | 26 2 | 11 1 | 2 9
0 + 200 | 190^**^,^j^ | 69^**^,^j^ | 86^g^ | 43^i^ | 44^i^
| 13 1 | 17 0 | 13 8 | 1 4 | 14 8
100 + 200 | 173^**^ | 50^*^ | 90^f^ | 40^i^ | 30^k^
| 11 6 | 14 6 | 22 3 | 7 8 | 14 2
200 + 200 | 152^**^ | 44 | 95 | 38^c^ | 32^e^
| 14 4 | 15 4 | 20 5 | 14 1 | 10 1
400 + 200 | 155^**^,^e^ | 63^*^,^e^ | 98^e^ | 50^c^ | 28^e^
| 14 2 | 8 0 | 26 9 | | 22 1
0 + 400 | 258^**^ | 153^**^ | 148^**^,^b^ | — | 84^e^
| 20 0 | 62 2 | 46 4 | | 49 4
100 + 400 | 208^**^,^c^ | 96^**^,^c^ | 110^c^ | — | —
200 + 400^l^ | — | — | — | — | —
400 + 400^l^ | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day) For each parameter, the mean is presented above the standard deviation, n=9, unless otherwise noted.

b n=7

c n=1, standard deviation not calculated due to high mortality

d Data were not available due to insufficient number of samples or insufficient sample

e n=3

f n=8

g n=6

h n=5

i n=2

j n=10

k n=4

l No data were available due to 100% mortality in this group

TABLE A4 Clinical Chemistry Data for Female Mice in the 13-Week Toxicity Study of AZT and Rifampicin Combinations^a^

Dose | ALP (U/L) | ALT (U/L) | AST (U/L) | SDH (U/L) | Bile Acids (μmol/L)
Day 4
0 + 0 | 243^b^ | 30^c^ | 81^d^ | 23^d^ | —^e^
| 25 2 | 2 7 | 19 8 | 7 1
100 + 0 | 202^f^ | 33^f^ | 84^g^ | — | —
| 29 4 | 10 0
200 + 0 | 234^b^ | 31^f^ | 75^h^ | 15^d^ | —
| 19 5 | 6 1 | 20 1 | 15 6
400 + 0 | 234^f^ | 26^c^ | 73^g^ | 19^g^ | —
| 16 6 | 2 0
0 + 100 | 231^f^ | 33^b^ | 97^h^ | 27^g^ | —
| 29 9 | 6 2 | 28 4
100 + 100 | 227 | 28^f^ | 91^g^ | 25^g^ | —
| 26 9 | 1 3
200 + 100 | 232 | 30^b^ | 82^i^ | 14^d^ | —
| 50 5 | 4 1 | 6 6 | 13 4
400 + 100 | 224^b^ | 31 | 67^h^ | — | —
| 24 4 | 3 5 | 7 0
0 + 200 | 229^f^ | 33^f^ | 93^g^ | — | —
| 28 5 | 6 3
100 + 200 | 231^f^ | 37^c^ | — | — | —
| 13 1 | 4 5
200 + 200 | 228^f^ | 33 | 88^d^ | 20^g^ | —
| 26 2 | 5 0 | 6 4
400 + 200 | 217 | 34^c^ | 85^g^ | 21^g^ | —
| 32 6 | 3 5
0 + 400 | 259^j^ | 41^h^ | — | — | —
| 25 4 | 1 2
100 + 400 | 219^b^ | 41^*^,^b^ | 91^i^ | 31^d^ | —
| 24 0 | 4 4 | 21 5 | 0 0
200 + 400 | 221^f^ | 40^*^,^k^ | 87^d^ | 28^d^ | —
| 22 7 | 12 3 | 12 7 | 2 1
400 + 400 | 202^h^ | 63^**^,^i^ | — | — | —
| 9 0 | 18 9
Day 30
0 + 0 | 142 | 26 | 71^j^ | 33^g^ | 79^g^
| 17 0 | 5 2 | 11 9
100 + 0 | 150^j^ | 43^k^ | 100^g^ | — | 58^g^
| 17 6 | 37 2
200 + 0 | 143^f^ | 39^f^ | 66^i^ | 5^g^ | —
| 24 3 | 29 9 | 22 6
400 + 0 | 140^b^ | 25^b^ | 82^k^ | — | 19^d^
| 17 5 | 5 2 | 19 2 | | 2 8
0 + 100 | 163^c^ | 43^c^ | 56^h^ | — | 130^g^
| 17 8 | 28 9 | 13 1
100 + 100 | 153 | 26 | 62^i^ | 21^g^ | —
| 15 7 | 5 0 | 9 3
200 + 100 | 156^b^ | 24^b^ | 73^j^ | 21^g^ | 39^d^
| 13 1 | 2 4 | 6 0 | | 17 7
400 + 100 | 147 | 22 | 62^j^ | 24^g^ | 74^d^
| 31 5 | 3 0 | 13 7 | | 47 4
0 + 200 | 193^**^ | 34 | 79^k^ | 23^g^ | 40^d^
| 26 5 | 8 7 | 6 6 | | 1 4
100 + 200 | 158 | 27 | 77^c^ | 43^d^ | 109^d^
| 14 3 | 3 7 | 23 2 | 9 9 | 41 0
200 + 200 | 141^b^ | 36^b^ | 61^f^ | 18^j^ | 108^h^
| 30 3 | 21 1 | 14 9 | 7 8 | 43 2
400 + 200 | 135^f^ | 25^f^ | 57^k^ | 25^h^ | 137^h^
| 15 7 | 4 9 | 6 9 | 3 1 | 52 5
0 + 400 | 200^**^,^c^ | 82^**^,^c^ | 103^**^,^i^ | — | —
| 19 9 | 76 7 | 15 8
100 + 400 | 173^*^ | 59^*^ | 73^f^ | 38^d^ | —
| 17 1 | 19 4 | 20 0 | 12 0
200 + 400 | 161^k^ | 35^k^ | 55^k^ | 27^d^ | —
| 12 2 | 6 4 | 4 4 | 0 0
400 + 400 | 169^d^ | 56^d^ | 77^g^ | — | —
| 38 2 | 19 8
Day 60
0 + 0 | 135 | 34 | 97^f^ | 29^d^ | 34^d^
| 9 5 | 17 7 | 20 4 | 0 7 | 10 6
100 + 0 | 129 | 30 | 78^b^ | 29^j^ | 24^i^
| 15 8 | 10 8 | 20 7 | 3 1 | 3 1
200 + 0 | 135^b^ | 30^b^ | 76^b^ | 27^i^ | 28^i^
| 21 9 | 9 5 | 17 5 | 5 6 | 7 7
400 + 0 | 121 | 40 | 73^f^ | 26^j^ | 33^j^
| 14 4 | 45 2 | 7 4 | 3 4 | 17 0
0 + 100 | 139 | 26 | 75 | 20^k^ | 33^c^
| 13 9 | 3 5 | 19 2 | 6 2 | 8 1
100 + 100 | 136 | 25 | 67 | 22^j^ | 43^i^
| 15 9 | 3 7 | 21 2 | 7 3 | 20 1
200 + 100 | 132 | 48 | 79 | 32^j^ | 44^j^
| 12 4 | 59 7 | 19 8 | 4 7 | 10 1
400 + 100 | 136^i^ | 27^i^ | 72^i^ | 26^h^ | 32^h^
| 8 5 | 1 4 | 15 6 | 7 6 | 13 9
0 + 200 | 166^**^ | 32 | 74 | 27^i^ | 45^j^
| 12 7 | 5 8 | 17 9 | 9 7 | 5 3
100 + 200 | 149^b^ | 28^b^ | 69^b^ | 26^k^ | 68^c^
| 12 5 | 6 7 | 15 5 | 4 5 | 40 9
200 + 200 | 129^g^ | 29^g^ | 108^g^ | 39^g^ | 37^g^
400 + 200^l^ | — | — | — | — | —
0 + 400 | 197^**^ | 75 | 98 | 44^*^,^c^ | 73^b^
| 27 5 | 26 4 | 20 8 | 7 8 | 34 4
100 + 400^l^ | — | — | — | — | —
200 + 400^l^ | — | — | — | — | —
400 + 400^l^ | — | — | — | — | —
Days 92 to 95
0 + 0 | 112 | 20 | 80^j^ | — | 30^h^
| 10 9 | 4 3 | 15 7 | | 8 5
100 + 0 | 115^f^ | 19^f^ | 77^c^ | — | 18^g^
| 8 5 | 3 7 | 11 9
200 + 0 | 109^c^ | 19^c^ | 74^k^ | 21^g^ | 32^d^
| 14 5 | 5 5 | 24 9 | | 9 2
400 + 0 | 108^b^ | 21^b^ | 90^f^ | 37^g^ | 40^h^
| 190 | 10 5 | 23 3 | | 31 2
0 + 100 | 136^c^ | 19^c^ | 67^j^ | — | 35^d^
| 11 7 | 2 6 | 12 9 | | 2 8
100 + 100 | 131^f^ | 22^f^ | 77^c^ | 27^d^ | 39^i^
| 16 2 | 10 2 | 17 1 | 6 4 | 18 5
200 + 100 | 125^f^ | 20^f^ | 79^c^ | 32^h^ | 33^h^
| 9 1 | 10 3 | 23 7 | 12 5 | 4 7
400 + 100 | 124^c^ | 15^c^ | 79^c^ | 31^i^ | 46^j^
| 22 9 | 4 0 | 32 9 | 5 7 | 27 2
0 + 200 | 152^**^,^b^ | 29^b^ | 86^c^ | 38^d^ | 34^h^
| 16 6 | 6 3 | 20 2 | 3 5 | 5 0
100 + 200 | 162^**^ | 29 | 82 | 34^c^ | 75^b^
| 25 9 | 16 1 | 18 8 | 7 1 | 43 0
200 + 200 | 183^**^,^i^ | 35^i^ | 143^i^ | 51^d^ | 80^i^
| 25 9 | 19 2 | 70 9 | 3 5 | 26 4
400 + 200^l^ | — | — | — | — | —
0 + 400 | 182^**^,^b^ | 85^**^,^b^ | 112^f^ | — | —
| 32 7 | 57 6 | 63 8
100 + 400^l^ | — | — | — | — | —
200 + 400^l^ | — | — | — | — | —
400 + 400^l^ | — | — | — | — | —

* Significantly different (P≤0.05) from the vehicle control group using analysis of variance followed by Dunnett’s test

** P≤0.01

a Daily gavage doses of AZT + rifampicin (mg/kg per day) For each parameter, the mean is presented above the standard deviation, n=10, unless otherwise noted

b n=9

c n=7

d n=2

e Data were not available due to insufficient number of samples or insufficient sample

f n=8

g n=1, standard deviation not calculated due to high mortality

h n=3

i n=4

j n=5

k n=6

l No data were available due to 100% mortality in this group