# References

Amin, N.M. (1989). Zidovudine for treating AIDS: What physicians need to know. Postgrad. Med. 86, 195–208.2662155
Ayers, K.M. (1988). Preclinical toxicology of Zidovudine: An overview. Am. J. Med. 85, (Suppl. 2A), 186–188.3044084
Barnes, P.F., Bloch, A.B., Davidson, P.T., and Snider, D.E., Jr. (1991). Tuberculosis in patients with human immunodeficiency virus infection. N. Engl. J. Med. 324, 1644–1650.2030721
Baron, D.N., and Bell, J.L. (1974). Serum enzyme changes in patients receiving antituberculosis therapy with rifampin or p-aminosalicylic acid, plus isoniazid and streptomycin. Tubercle 55, 115–120.4620296
Bederka, J.P., Jr., Davitiyananda, D., Moses, M.L., and Amad, N. (1975). Drug-biomolecule interactions: Drug toxicity and vitamin coenzyme depletion. J. Pharm. Sci. 64, 528–534.239196
Centers for Disease Control (CDC) (1987). Diagnosis and management of mycobacterial infection and diseas in persons with human immunodeficiency virus infection. Ann. Intern. Med. 106, 254–256.3800186
Coffin, J.M. (1986). Genetic variation in AIDS viruses. Cell 46, 1–4.3013415
Dixon, W.J., and Massey, F.J., Jr. (1951). Introduction to Statistical Analysis, 1st ed., pp. 145–147. McGraw-Hill Book Company, Inc., New York.
Dunn, O.J. (1964). Multiple comparisons using rank sums. Technometrics 6, 241–252.
Dunnett, C.W. (1955). A multiple comparison procedure for comparing several treatments with a control. J. Am. Stat. Assoc. 50, 1095–1121.
East and Central African/British Medical Research Council (1986). Fifth collaborative study. Controlle clinical trial of 4 short-course regimens of chemotherapy (three 6-month and one 8-month) for pulmonary tuberculosis: Final report. Tubercle 67, 5–15.3521015
Goldschmidt, R.H., and Dong, B.J.. (1992). Current report—HIV treatment of AIDS and HIV-related conditions: 1992. J. Am. Board Fam. Pract. 5, 335–350.1580182
Gottlieb, M.S., Schroff, R., Schanker, H.M., Weisman, J.D., Fan, P.T., Wolf, R.A., and Saxon, A. (1981). Pneumocystis carinii pneumonia and mucosal candidiasis in previously healthy homosexual men: Evidence of a new acquired cellular immunodeficiency. N. Engl. J. Med. 305, 1425–1431.6272109
Greene, J.A., Ayers, K.M., deMiranda, P., and Tucker, W.E. (1990). Postnatal survival in Wistar rats following oral dosage with zidovudine on gestation day 10. Fundam. Appl. Toxicol. 15, 201–206.2373299
Grossett, J., Truffot-Pernot, C., Lacroix, C., and Ji, B. (1992). Antagonism between isoniazid and the combination pyrazinamide-rifampin against tuberculosis infection in mice. Antimicrob. Agents Chemother. 36, 545–551.1622163
Hardy, W.D. (1991). Prophylaxis of AIDS-related opportunistic infections (OIs). AIDS Clin. Rev. 145–180.1651099
Harkins, T., and Herriot, K.B. (1992). Medical management of acquired immune deficiency syndrome patients: A review. J. Am. Optom. Assoc. 63, 35–42.1583259
Jeffries, D.J. (1989). Targets for antiviral therapy of human immunodeficiency virus infection. J. Inject. 18 (Suppl. 1), 5–13.
Jonckheere, A.R (1954). A distribution-free k-sample test against ordered alternatives. Biometrika 41, 133–145.
Mandell, G.L., and Sande, M.A. (1990). Drugs used in the chemotherapy of tuberculosis and leprosy. In Goodman and Gilman’s The Pharmacological Basis of Therapeutics (A.G. Gilman, T.W. Rall, A.S. Nies, and P. Taylor, Eds.), 8th ed., pp. 1146–1164. Pergaman Press, New York.
Mansuri, M.M., Hitchcock, M.J., Buroker, RA., Bregman, C.L., Ghazzouli, I., Desiderio, J.V., Starrett, J.E., Sterzycki, R.Z., and Martin, J.C. (1990). Comparison of in vitro biological properties and mouse toxicities of three thymidine analogs active against human immunodeficiency virus. Antimicrob. Agents Chemother. 34, 637–641.1693057
Masur, H., Michelis, M.A., Greene, J.B., Onorato, I., Vande Stouwe, R.A., Holzman, R.S., Wormser, G., Brettman, L., Lange, M., Murray, H.W., and Cunningham-Rundles, S. (1981). An outbreak of community-acquired Pneumocystis carinii pneumonia: Initial manifestations of cellular immune dysfunction. J. Immunol. 135, 3151–3162.
National Institute of Environmental Health Sciences (NIEHS) (1997). Reproductive, Developmental, and General Toxicity Studies of Pyrazinamide Administered by Gavage to Swiss (CD-1®) Mice. NIEHS AIDS Therapeutics Toxicity Report No. 1. NIH Publication 97-3938. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
National Toxicology Program (NTP) (1999). Toxicology and Carcinogenesis Studies of AZT (CAS No. 30516-87-1) and AZT/α-Interferon A/D in B6C3F_1_ Mice (Gavage Studies). Technical Report Series No. 469. NIH Publication No. 99-3959. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Research Triangle Park, NC.
Nolan, C.M. (1992). Human immunodeficiency syndrome-associated tuberculosis: A review with an emphasis on infection control issues. Am. J. Infect. Control 20, 30–34.1554145
Ramakrishnan, C.V., Janardhanam, B., Krishnamurthy, D.V., Stott, H., Subbammal, S., and Tripathy, S.P. (1968). Toxicity of pyrazinamide administered once weekly in high dosage in tuberculosis patients. Bull. W.H.O. 39, 775–779.5306313
Rao, G.N., Lindamood, C. III., Heath, J.E., Farnell, D.R, and Giles, H.D. (1998). Subchronic toxicity of human immunodefficiency virus and tuberculosis combination therapies in B6C3F_1_ mice. Toxicol. Sci. 45, 113–127.9848118
Registry of Toxic Effects of Chemical Substances (RTECS) (1983). 1981–1982 Edition, Vol. 3 (P-Z), p. 393. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Cincinnati. OH.
Richman, D.D. (1988). The treatment of HIV infection. Azidothymidine (AZT) and other new antiviral drugs. Infec. Dis. Clin. North Am. 2, 397–497.2462584
Roman, I.C., and Georgian, L. (1977). Cytogenetic effects of some anti-tuberculosis drugs in vitro. Mutat. Res. 48, 215–224.876269
Shirley, E. (1977). A non-parametric equivalent of Williams’ test for contrasting increasing dose levels of a treatment. Biometrics 33, 386–389.884197
Siegle, FP., Lopez, C., Hammer, C.S., Brown, A.E., Kornfeld, S.J., Gold, J., Hassett, J., Hirschman, S.Z., Cunningham-Rundles, C., Adelsberg, B.R., Parham, D.M., Siegal, M., Cunningham-Rundles, S., and Armstrong, D. (1981). Severe acquired immunodeficiency in male homosexuals manifested by chronic perianal ulcerative herpes simplex lesions. N. Engl. J. Med. 305, 1439–1444.6272110
Stevens, J. (1986). Applied Multivariate Statistics for the Social Sciences. Chapter 3. LEA Publishers.
Toltzis, P., Marx, C.M., Kleinman, N., Levine, E.M., and Schmidt, E.V. (1991). Zidovudine-associated embryonic toxicity in mice. J. Infect. Dis. 163, 1212–1218.2037787
Trang, J.M., Prejean, J.D., James, R.H., Irwin, R.D., Goehl, T.J., and Page, J.G. (1993). Zidovudine bioavailability and linear pharmacokinetics in female B6C3F1 mice. Drug Metab. Dispos. 21, 189–193.8095218
Vince, R., Hua, M., Brownell, J., Daluge, S., Lee, F.C., Shannon, W.M., Lavelle, G.C., Qualls, J., Weislow, O.S., Kiser, R., Canonico, C.G., Schultz, R.H., Narayanan, V.L., Mayo, L.G., Shoemaker, R.H., and Boyd, M.R. (1988). Potent and selective activity of a new carbocyclic nucleoside analog (Carbovir: NSC 614846) against human immunodeficiency virus in vitro. Biochem. Biophys. Res. Commun. 156, 1046–1053.2847711
Weiner, I.M., and Tinker, J.P. (1972). Pharmacology of pyrazinamide: Metabolic and renal function studies related to the mechanism of drug-induced urate retention. J. Pharmacal. Exp. Ther. 180, 411–434.
Williams, D.A. (1971). A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 27, 103–117.5547548
Williams, D.A. (1972). The comparison of several dose levels with a zero dose control. Biometrics 28, 519–531.5037867
Zitkova, L., Stastna, J., Tousek, J., and Viklicky, J. (1983). Toxicity of morphazinamide compared with pyrazinamide. Czech. Med. 6, 140–151.6416791