# Peer Review

The report on the subchronic toxicity study of 3′-azido-3′-deoxythymidine (AZT) and pyrazinamide combinations was evaluated by the reviewers listed below. These reviewers serve as independent scientists, not as representatives of any institution, company, or governmental agency. In this capacity, reviewers determine if the design and conditions of these studies are appropriate and ensure that this general toxicity study report presents the experimental results and conclusions fully and clearly. The comments of the reviewers were reviewed prior to the finalization of this document. Changes were made such that the concerns of the reviewers were addressed to the extent possible.

- Curtis D. Klaassen, Ph.D.
  Department of Pharmacology and Toxicology
  University of Kansas Medical Center
  Kansas City, KS
- Paul T. Bailey, Ph.D.
  Mobile Business Resources Corporation
  Paulsboro, NJ