# Discussion and Conclusions

Tuberculosis is one of the most common opportunistic infections in AIDS patients, and these patients frequently receive combination therapy with pyrazinamide and AZT. In this study, administration of pyrazinamide at 1,000 or 1,500 mg/kg did not cause any biologically significant changes in hematologic parameters; however, minor statistically significant increases in hemoglobin concentration at the end of the study (days 92 to 95) were observed in male and female mice (Tables A1 and A2). AZT at 200 or 400 mg/kg caused a dose-related increase in severity of hematologic toxicity. Pyrazinamide at 1,000 mg/kg did not markedly increase the toxicity of AZT at doses up to 400 mg/kg. Pyrazinamide at 1,500 mg/kg, when coadministered with AZT at 400 mg/kg, caused more severe hematologic changes than those caused by AZT alone (Tables A1 and A2). These changes included significant decreases in erythrocyte counts and significant increases in platelet counts (Tables A1 and A2). An initial reticulocytopenia was observed on day 4 followed by reticulocytosis on days 30 and 60 and at the end of the study (days 92 to 95), indicating a regenerative response of the hematopoietic system. Pyrazinamide did not markedly influence the cellular depletion of bone marrow caused by AZT alone. AZT at 400 mg/kg caused a significant increase in the incidence but not the severity of glycogen depletion in the liver. Pyrazinamide, at the doses tested, caused increases in liver weights and increased the incidence and severity of liver glycogen depletion. These effects of pyrazinamide were not enhanced by coadministration of AZT. Pyrazinamide alone decreased the testicular, caudal and epididymal weights and epididymal sperm motility. AZT alone caused deceases in testicular weights and epididymal sperm motility. There appears to be some interaction between AZT and pyrazinamide on epididymal sperm motility.

## Conclusions

AZT caused a dose-related increase in the severity of hematological toxicity. Pyrazinamide up to 10 times the therapeutic dose (1,500 mg/kg) did not cause general or hematologic toxicity. However, 10 times the therapeutic dose of pyrazinamide increased the hematologic toxicity of AZT, indicating that pyrazinamide at high doses may have potentiated the hematologic toxicity of AZT.