# Results

## Survival and Clinical Findings

Four mice from the clinical pathology groups died before the end of the study. One female mouse from the 1,000 mg/kg pyrazinamide group died on day 9 from an apparent dosing accident. One male from the 400 + 1,000 mg/kg AZT + pyrazinamide group, one female from the 400 mg/kg AZT group, and one female from the 400 + 1,500 mg/kg AZT + pyrazinamide group either died or were sacrificed in moribund condition on day 30 or 31. These three deaths were thought to be the result of the bleeding procedure being performed on animals that had an underlying anemia. None of the deaths were thought to have been directly caused by the administration of the test article. There were no significant clinical findings in mice treated with AZT alone, pyrazinamide alone, or the AZT and pyrazinamide combinations. However, all mice treated with AZT or AZT with pyrazinamide had darkening of the skin on the tail, feet, and muzzle.

## Body and Organ Weights

### Male Mice

The administration of AZT alone, pyrazinamide alone, and AZT and pyrazinamide combined did not result in any significant changes in mean body weight gain in male B6C3F_1_ mice during the course of this study (Figure 1). For male mice treated with 400 mg/kg AZT alone, a slight decrease in the final mean body weights occurred. The final mean body weight (33.8 g) was approximately 6% less than that of the vehicle control group (36.1 g; Table B1). There were no significant decreases in final mean body weights in any of the groups treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide.

Slight treatment-related increases were evident in the liver weights of male mice treated with pyrazinamide alone or combinations of pyrazinamide and AZT (Figure 2 and Table B1). There were no significant changes in absolute kidney weights of male mice treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide. Increases in thymus weights occurred in male mice administered 1,000 mg/kg pyrazinamide and male mice administered 200 + 1,500 mg/kg (Table B1). These increases were not considered to be biologically significant because dose-related patterns were not evident. Slight increases in heart weights were observed in males treated with 400 + 1,000 mg/kg or 400 + 1,500 mg/kg (Table B1). The increased relative heart weights may represent a compensatory myocardial hypertrophy in anemic animals subsequent to increased heart rate and/or force of contraction in an attempt to maintain adequate tissue oxygenation. Significant changes were not observed in lung weights of male mice treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide. Absolute right testis weights were lower in the group treated with 400 mg/kg AZT and in all groups treated with pyrazinamide alone or in combination with AZT (Table B1). Changes of greatest magnitude were observed in the group treated with 400 + 1,500 mg/kg, in which the absolute testis weight was approximately 20% less than that of the vehicle control group.

FIGURE 1 Mean Body Weights of Male Mice in the 13-Week Study of AZT and Pyrazinamide Combinations

FIGURE 2 Mean Absolute Liver Weights for Male and Female Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

### Female Mice

Administration of AZT alone, pyrazinamide alone, and combinations of AZT and pyrazinamide to female B6C3F_1_ mice did not result in any significant alterations in mean body weight gain during the course of the study (Figure 3). For female mice treated with 1,500 mg/kg pyrazinamide, a slight increase in final mean body weight occurred (Table B1). The final mean body weight (29.8 g) was approximately 1.05 times that of the vehicle control group (28.4 g). Statistically significant decreases in final mean body weights were not observed in any of the groups treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide.

Treatment-related increases were evident in the liver weights of female mice treated with pyrazinamide alone or combinations of pyrazinamide and AZT (Figure 2 and Table B1). The liver weights of female mice treated with 1,000 or 1,500 mg/kg pyrazinamide alone were approximately 1.16 times (1.381 g; P≤0.05) and 1.26 times (1.509 g; P≤0.05) the weight of the corresponding vehicle control group (1.195 g). Liver weights were increased in all dosed groups that received combinations of AZT and pyrazinamide. For female mice receiving combination therapy, the highest liver weights were observed in the group administered 200 + 1,500 mg/kg: the absolute liver weight was approximately 1.31 times (1.563 g; P≤0.05) that of the vehicle control group (1.195 g). The absolute kidney weights of female mice administered 1,500 mg/kg and of all female groups treated with combination therapy (Table B1) were increased. The significance of these increased kidney weights was not known. There were no significant changes in thymus weights of female mice. Increases in heart weights were observed in all female groups administered AZT and pyrazinamide in combination (Table B1). Increased heart weights of the combination groups were approximately 1.10 to 1.14 times (0.125 to 0.129 g) the weight of the vehicle control group (0.113 g). These increases in heart weights may represent a compensatory myocardial hypertrophy in anemic animals subsequent to increased heart rate and/or force of contraction in an attempt to maintain adequate tissue oxygenation. The increased relative heart weight of female mice administered 1,000 mg/kg pyrazinamide was thought to be an incidental finding, as a dose-related pattern was not evident. Significant changes were not detected in lung weights of female mice treated with AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide (Table B1).

FIGURE 3 Mean Body Weights of Female Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

## Hematology

### AZT Alone

Administration of 200 or 400 mg/kg AZT alone produced anemia, reticulocytopenia followed by reticulocytosis, thrombocytosis, and leukopenia. In general, alterations were more prevalent in females than in males. The anemic process was mild, usually dose related, and accompanied by elevations in mean cell volume (MCV) and mean cell hemoglobin (MCR) values and, as such, could be classified as macrocytic. On day 4, slight decreases were detected in erythrocyte (RBC) counts of male mice treated with AZT alone. Respective RBC counts of male mice administered 200 or 400 mg/kg AZT were approximately 5% (9.02 × 10^6^/mm^3^; P≤0.05) and 6% (8.90 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (9.45 × 10^6^/mm^3^) (Figure 4 and Table A1). Minor decreases in hemoglobin (Hgb) and hematocrit (Hct) values accompanied the treatment-related decreases in RBC counts. Significant changes were not detected in any of the RBC parameters evaluated on day 4 in female mice administered AZT alone (Figure 5 and Table A2).

On day 30, significant (P≤0.01) dose-related decreases in RBC counts were detected in male and female mice administered AZT alone. Respective RBC counts of male mice administered 200 or 400 mg/kg AZT were approximately 17% (8.47 × 10^6^/mm^3^; P≤0.01) and 23% (7.89 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (10.22 × 10^6^/mm^3^) (Figure 4 and Table A1). Declines in Hgb and Hct values paralleled the decreased RBC counts and were accompanied by significant increases in MCVs and MCH values. For female mice on day 30, respective RBC counts for groups administered 200 or 400 mg/kg AZT were approximately 16% (7.92 × 10^6^/mm^3^; P≤0.01) and 21% (7.46 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (9.45 × 10^6^/mm^3^) (Figure 5 and Table A2). Minor decreases in Hgb and Hct values and significant increases in MCV and MCH values (P≤0.01) accompanied the dose-related decreases in RBC counts. Minor significant decreases in mean cell hemoglobin concentration (MCHC) values of the female mice were not considered to be biologically significant.

On day 60, changes in RBC parameters of male and female mice administered AZT alone were similar to those observed on day 30. Respective RBC counts of male mice administered 200 or 400 mg/kg AZT were approximately 21% (8.38 × 10^6^/mm^3^; P≤0.01) and 27% (7.81 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (10.63 × 10^6^/mm^3^) (Figure 4 and Table A1). Hgb and Hct values paralleled the decreases in RBC counts, and significant increases (P≤0.01) in MCV and MCH values also accompanied the anemia. Respective MCV values of male mice administered 200 or 400 mg/kg AZT were approximately 16% (56.3 fL; P≤0.01) and 23% (59.6 fL; P≤0.01) greater than that of the vehicle control group (48.6 fL).

FIGURE 4 Mean Red Blood Cell Values for Male Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

FIGURE 5 Mean Red Blood Cell Values for Female Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

Similar changes were observed in female mice on day 60. Respective mean RBC counts of female mice treated with 200 or 400 mg/kg AZT were approximately 24% (7.55 × 10^6^/mm^3^; P≤0.01) and 28% (7.19 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (9.98 × 10^6^/mm^3^) (Figure 5 and Table A2). Decreased Hgb and Hct values accompanied the dose-related decreases in RBC counts. MCV values of female mice administered 200 or 400 mg/kg AZT were approximately 19% (58.5 fL; P≤0.01) and 27% (62.4 fL; P≤0.01) greater than that of the vehicle control group (49.3 fL). Minor significant decreases in MCHC values of males and females were not believed to be biologically significant.

An anemia of similar magnitude was observed in male and female mice at the time of terminal sacrifice on days 92 to 95. Respective RBC counts of male mice treated with 200 or 400 mg/kg AZT were approximately 18% (8.44 × 10^6^/mm^3^; P≤0.01) and 24% (7.83 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (10.28 × 10^6^/mm^3^) (Figure 4 and Table A1). Decreased Hgb and Hct values paralleled the dose-related decreases in RBC counts. Increased MCV and MCH values (P≤0.01) also accompanied the compound-related anemia. MCV values observed at the time of terminal sacrifice in male mice treated with 200 or 400 mg/kg AZT were approximately 16% (54.6 fL; P≤0.01) and 22% (57.5 fL; P≤0.01) greater than that of the vehicle control group (47.1 fL).

Changes observed in the RBC parameters of female mice at the end of the study were similar to those described in males. Respective RBC counts of female mice administered 200 or 400 mg/kg AZT alone were approximately 19% (7.85 × 10^6^/mm^3^; P≤0.01) and 26% (7.13 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle control group (9.65 × 10^6^/mm^3^) (Figure 5 and Table A2). Decreases in Hgb and Hct values paralleled the dose-related decreases in RBC counts. Increases in MCV and MCH values (P≤0.01) also accompanied the dose-related anemia. Respective MCV values of female mice administered 200 or 400 mg/kg AZT alone were approximately 19% (55.7 fL; P≤0.01) and 26% (59.3 fL; P≤0.01) greater than that of the vehicle control group (46.9). No other significant changes were observed in the RBC parameters evaluated in male or female mice administered AZT alone.

Administration of AZT alone to male and female mice also produced statistically and biologically significant alterations in reticulocyte counts. Initially, a reticulocytopenia developed, which was followed by a reticulocytosis later in the study. Respective reticulocyte counts on day 4 of male mice treated with 200 or 400 mg/kg AZT alone were approximately 28% (3.4 × 10^5^/mm^3^; P≤0.01) and 32% (3.2 × 10^5^/mm^3^; P≤0.01) less than that of the vehicle control group (4.7 × 10^5^/mm^3^) (Table A1). Respective reticulocyte counts on day 4 of female mice treated with identical doses were approximately 20% (3.3 × 10^5^/mm^3^; P≤0.05) and 27% (3.0 × 10^5^/mm^3^; P≤0.01) less than that of the vehicle control females (4.1 × 10^5^/mm^3^) (Table A2). Reticulocyte counts rebounded rapidly, as a dose-related reticulocytosis was evident in male and female mice on day 30. Respective reticulocyte counts on day 30 of male mice administered 200 or 400 mg/kg AZT were approximately 1.1 times (4.3 × 10^5^/mm^3^) and 1.3 times (5.1 × 10^5^/mm^3^; P≤0.01) the reticulocyte count of the vehicle controls (4.0 × 10^5^/mm^3^). Respective reticulocyte counts of the female groups treated with identical doses were approximately 1.3 times (4.1 × 10^5^/mm^3^; P≤0.05) and 1.5 times (4.7 × 10^5^/mm^3^) the reticulocyte count of the vehicle controls (3.1 × 10^5^/mm^3^).

A dose-related reticulocytosis was also evident in male and female mice on day 60. Respective reticulocyte counts on day 60 of male mice treated with 200 or 400 mg/kg AZT alone were approximately 1.2 times (4.0 × 10^5^/mm^3^; P≤0.01) and 1.6 times (5.1 × 10^5^/mm^3^; P≤0.01) the reticulocyte count of the vehicle controls (3.3 × 10^5^/mm^3^) (Table A1). Respective reticulocyte counts on day 60 of female mice treated with identical doses were approximately 1.4 times (4.9 × 10^5^/mm^3^; P≤0.01) and 1.7 times (5.9 × 10^5^/mm^3^; P≤0.01) greater than that of the vehicle controls (3.5 × 10^5^/mm^3^) (Table A2).

A dose-related reticulocytosis similar to that described above was observed in male and female mice at the end of the study. Respective reticulocyte counts at terminal sacrifice of male mice treated with 200 or 400 mg/kg AZT alone were approximately 1.3 times (5.4 × 10^5^/mm^3^; P≤0.01) and 1.4 times (6.0 × 10^5^/mm^3^; P≤0.01) that of the vehicle control group (4.3 × 10^5^/mm^3^) (Table A1). Respective reticulocyte counts at the end of the study of female mice treated with identical doses were approximately 1.1 times (4.9 × 10^5^/mm^3^) and 1.4 times (6.0 × 10^5^/mm^3^; P≤0.01) that of the reticulocyte count of the vehicle control group (4.3 × 10^5^/mm^3^) (Table A2).

A compound-related increase in platelets, although not always statistically significant, was observed in male and female mice treated with AZT alone. Respective platelet counts observed on day 30 of male mice administered 200 or 400 mg/kg AZT alone were approximately 1.1 times (1,275 × 10^3^/mm^3^) and 1.1 times (1,293 × 10^3^/mm^3^) that of the platelet count of the vehicle controls (1,150 × 10^3^/mm^3^) (Table A1). Respective platelet counts on day 30 of female mice administered doses identical to the male doses were approximately 1.1 times (1,171 × 10^3^/mm^3^) and 1.2 times (1,209 × 10^3^/mm^3^; P≤0.05) that of the platelet count of the vehicle controls (1,044 × 10^3^/mm^3^) (Table A2).

A compound-related thrombocytosis was evident on day 60. Respective platelet counts on day 60 of male mice administered 200 or 400 mg/kg AZT alone were approximately 1.3 times (1,259 × 10^3^/mm^3^; P≤0.01) and 1.4 times (1,305 × 10^3^/mm^3^; P≤0.01) that of the platelet count of the vehicle control group (949 × 10^3^/mm^3^) (Table A1). Respective platelet counts obtained on day 60 of female mice treated with identical doses were approximately 1.3 times (1,276 × 10^3^/mm^3^; P≤0.01) and 1.3 times (1,292 × 10^3^/mm^3^; P≤0.01) that of the vehicle control group (1,010 × 10^3^/mm^3^) (Table A2).

Although not statistically significant, platelet counts of male and female mice treated with AZT alone were slightly increased at the end of the study (days 92 to 95). Respective platelet counts at the end of the study of male mice administered 200 or 400 mg/kg AZT alone were approximately 1.1 times (1,520 × 10^3^/mm^3^) and 1.1 times (1,502 × 10^3^/mm^3^) that of the vehicle controls (1,347 × 10^3^/mm^3^) (Table A1). Respective platelet counts of female mice treated with identical doses were approximately 1.1 times (1,275 × 10^3^/mm^3^) and 1.1 times (1,319 × 10^3^/mm^3^) that of the vehicle controls (1,176 × 10^3^/mm^3^) (Table A2).

Administration of AZT alone also resulted in a leukopenia that appeared to be more pronounced in female mice than in males. On day 4, statistically significant changes in leukocyte (WBC) values were not observed in male mice treated with AZT alone (Figure 6 and Table A1). For the female mice, respective WBC counts of the groups treated with 200 or 400 mg/kg AZT alone were approximately 29% (5.77 × 10^3^/mm^3^; P≤0.01) and 30% (5.64 × 10^3^/mm^3^; P≤0.01) less than that of the vehicle controls (8.11 × 10^3^/mm^3^) (Figure 7 and Table A2). Evaluation of the corresponding differential data revealed declines in both granulocytes and mononuclear cell counts.

On day 30, similar findings were evident in the WBC parameters of male and female mice, as biologically significant alterations were not observed in male mice treated with AZT alone (Table A1). WBC counts on day 30 of female mice administered 200 or 400 mg/kg AZT alone were approximately 15% (4.47 × 10^3^/mm^3^) and 32% (3.58 × 10^3^/mm^3^; P≤0.01) less than that of the vehicle controls (5.24 × 10/mm^3^) (Table A2). Evaluation of the corresponding differential data revealed dose-related significant declines in segmented neutrophil, lymphocyte, and monocyte counts.

On day 60, only minor alterations were evident in some of the WBC parameters evaluated in male and female mice treated with AZT alone (Tables A1 and A2). Although significant decreases were not detected in the WBC counts of male or female mice, minor decreases were evident in segmented neutrophil and monocyte counts of males and females. At the end of the study (days 92 to 95), although not statistically significant, slight declines were evident in WBC, segmented neutrophil, lymphocyte, and monocyte counts. The only statistically significant change observed at the end of the study was a decreased eosinophil count of male mice administered 400 mg/kg AZT.

FIGURE 6 Mean Leukocyte Values for Male Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

FIGURE 7 Mean Leukocyte Values for Female Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

### Pyrazinamide Alone

Administration of pyrazinamide at concentrations of 1,000 or 1,500 mg/kg to male and female mice did not result in any biologically significant alterations in any of the hematology parameters evaluated during this study. Occasional significant changes in some parameters were observed with a random or sporadic distribution. On day 4, a minor significant increase in monocyte counts was observed in male mice administered 1,500 mg/kg. This change was not considered to be biologically significant, as an overall leukocytosis was not observed. Also on day 4, minor statistically significant decreases were observed in WBC, lymphocyte, and eosinophil counts of female mice treated with 1,000 mg/kg. These decreased values were not considered to be biologically significant, as a dose-related response was not evident, and female mice administered 1,500 mg/kg had no significant changes in any of the parameters evaluated. On day 30, minor significant increases were observed in segmented neutrophil and monocyte counts of the male groups treated with 1,000 or 1,500 mg/kg. A significant decrease was also observed in the eosinophil count of the male group treated with 1,500 mg/kg. Those minor changes in differential parameters were not considered to be biologically significant, as WBC counts were not altered. A significant increase in MCH values of males administered 1,500 mg/kg was within normal limits. Significant changes were not observed in female groups on day 30. On day 60, significant increases in MCH values of male and female mice of the 1,500 mg/kg groups and a minor increase in MCHC values of female mice administered 1,500 mg/kg were considered to be within normal limits.

At the end of the study for mice administered pyrazinamide alone (days 92 to 95), increases in Hgb values of male and female mice in both dose groups and increases in MCH values of female mice in the 1,500 mg/kg group were within normal limits. Significant decreases in eosinophil counts of male mice in the 1,000 and 1,500 mg/kg groups were not considered to be biologically significant, as alterations in WBC counts were not observed.

### AZT/Pyrazinamide Combinations

In general, administration of combinations of AZT and pyrazinamide to male and female mice resulted in hematologic alterations of far greater magnitude than those observed subsequent to the administration of AZT alone. Although overt anemia was not evident in male or female mice on day 4, statistically significant declines in RBC counts were observed in male mice treated with combinations of AZT and pyrazinamide. These slight decreases were similar in magnitude among the different combination groups (Figure 4 and Table A1). Slight declines in Hgb and Hct values accompanied the decreased RBC counts. Significant changes were not observed in the RBC parameters evaluated on day 4 of female mice administered combinations of AZT and pyrazinamide.

On day 30, the severity of the anemia had increased, and male mice administered combinations of AZT and pyrazinamide were more anemic than those treated with AZT alone. On day 30, the RBC count of male mice administered 400 + 1,500 mg/kg was approximately 28% (7.40 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle controls (10.22 × 10^6^/mm^3^) (Figure 4 and Table A1). Decreased Hgb and Hct values paralleled the decline in RBC count, and significant increases (P≤0.01) in MCV and MCH values also accompanied the anemia. The peak MCV value of male mice administered 400 + 1500 mg/kg was approximately 18% (61.4 fL; P≤0.01) greater than that of the vehicle controls (52.0 fL). An anemia of similar magnitude was observed in female mice on day 30, except that the only difference between the effect of AZT alone versus combination treatment was in the 400 + 1,500 mg/kg group. The RBC count of the female group receiving 400 mg/kg AZT alone was 23% less than that of the vehicle control group, and the RBC count of the 400 + 1,500 mg/kg group was 29% less than that of the vehicle control group. The RBC count of the high-dose combination group was 6.70 × 10^6^/mm^3^ (P≤0.01) versus 9.45 × 10^6^/mm^3^ for the female vehicle control group. Dose-related declines in Hgb and Hct values paralleled the treatment-related decrease in the RBC counts. Increased MCV and MCH values (P≤0.01) also accompanied the anemia. The MCV value on day 30 of the female group administered 400 + 1,500 mg/kg was approximately 16% (56.5 fL; P≤0.01) greater than that (48.9 fL) of the vehicle control group. Minor significant decreases in MCHC values observed in male and female mice administered combinations of AZT and pyrazinamide were considered to be within normal limits.

On day 60, the magnitude of the changes in RBC parameters was slightly greater in both males and females than those described for day 30, and the changes were dose related. On day 60, the RBC count of male mice administered 400 + 1,500 mg/kg was approximately 36% (6.84 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle controls (10.63 × 10^6^/mm^3^) (Figure 4 and Table A1). Hgb and Hct values paralleled the decreases in RBC counts. Marked compound-related increases in MCV and MCH values (P≤0.01) accompanied the anemia. The peak MCV value observed on day 60 of male mice administered 400 + 1,500 mg/kg was approximately 34% (65.3 fL; P≤0.01) greater than that of the vehicle controls (48.6 fL). An anemia of similar magnitude was evident on day 60 in female mice administered combinations of AZT and pyrazinamide. The RBC count (Figure 5) on day 60 of female mice administered 400 + 1,500 mg/kg was approximately 36% (6.34 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle controls (9.98 × 10^6^/mm^3^). Hgb and Hct values paralleled the decrease in RBC counts, and marked increases in MCV and MCH values (P≤0.01) also accompanied the dose-related anemia. The peak MCV value observed on day 60 of female mice administered 400 + 1,500 mg/kg was approximately 30% (64.3 fL; P≤0.01) greater than that (49.3 fL) of the vehicle controls. Minor changes in MCHC values observed in both males and females were considered to be within normal limits.

At the end of the study (days 92 to 95), the anemia in male and female mice treated with combinations of AZT and pyrazinamide was similar to that described for day 60. At the end of the study, the RBC count of male mice administered 400 + 1,500 mg/kg was approximately 33% (6.89 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle controls (10.28 × 10^6^/mm^3^ (Figure 4 and Table A1). Decreased Hgb and Hct values paralleled the compound-related decrease in RBC counts. Marked increases in MCV and MCR values (P≤0.01) also accompanied the anemia. The peak MCV value of male mice administered 400 + 1,500 mg/kg was approximately 34% (63.1 fL; P≤0.01) greater than that of the vehicle controls (47.1 fL). A treatment-related anemia of similar severity was observed at the end of the study in female mice treated with combinations of AZT and pyrazinamide. The RBC count (Figure 5 and Table A2) of female mice administered 400 + 1,500 mg/kg was approximately 30% (6.76 × 10^6^/mm^3^; P≤0.01) less than that of the vehicle controls (9.65 × 10^5^/mm^3^). Decreased Hgb and Hct values paralleled the decreases in reticulocyte counts, and marked increases in MCV and MCR values (P≤0.01) also accompanied the anemia. The peak MCV value observed in female mice administered 400 + 1,500 mg/kg was approximately 36% (63.6 fL; P≤0.01) greater than that of the vehicle controls (46.9 fL). Minor changes in MCHC values observed in male and female mice administered combinations of AZT and pyrazinamide were considered to be within normal limits.

Male and female mice administered combinations of AZT and 1,500 mg/kg pyrazinamide developed a prominent reticulocytopenia early (day 4) in the study, and the severity of this change was greater than that observed subsequent to the administration of AZT alone. Combinations of AZT and 1,000 mg/kg pyrazinamide had little or no effect on the reticulocytopenia compared with the administration of AZT alone. The reticulocyte count on day 4 of the male group treated with 400 + 1.500 mg/kg was approximately 43% (2.7 × 10^5^/mm^3^; P≤0.01) less than that of the vehicle controls (4.7 × 10^5^/mm^3^) (Table A1). The reticulocyte count on day 4 of female mice administered the identical combination was approximately 37% (2.6 × 10^5^/mm^3^; P≤0.01) less than that of the vehicle controls (4.1 × 10^5^/mm^3^) (Table A2).

Reticulocyte counts rebounded rapidly, and a significant reticulocytosis was evident by day 30. All combinations of AZT and pyrazinamide in males caused an increase in reticulocytosis in comparison to males administered AZT alone. The reticulocyte count of male mice administered 400 + 1,500 mg/kg was approximately 1.4 times (5.6 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (4.0 × 10^5^/mm^3^) (Table A1). The magnitude of reticulocytosis was also increased in females receiving combinations of AZT and pyrazinamide; however, the effect at 400 + 1,000 mg/kg was greater than that at 400 + 1,500 mg/kg (Table A2). The reticulocyte count of female mice administered 400 + 1,000 mg/kg was approximately 1.7 times (5.4 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (3.1 × 10^5^/mm^3^).

The reticulocytosis on day 60 in male and female mice administered combinations of AZT and pyrazinamide was similar to that described for day 30. The reticulocyte count observed on day 60 of male mice administered 400 + 1,500 mg/kg was approximately 1.9 times (6.1 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (3.3 × 10^5^/mm^3^) (Table A1). In females, as on day 30, the magnitude of reticulocytosis in the group administered 400 + 1,000 mg/kg was greater than that in the group given 400 + 1,500 mg/kg (Table A2). The reticulocyte count on day 60 of female mice administered 400 + 1,000 mg/kg was approximately 1.7 times (6.1 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (3.5 × 10^5^/mm^3^).

At the end of the study (days 92 to 95), the reticulocytosis in male and female mice was dose related, and the magnitude of this change was greater in groups administered the highest combinations of AZT and pyrazinamide when compared to groups treated with AZT alone. The reticulocyte count at the end of the study for male mice administered 400 + 1,500 mg/kg was approximately 1.8 times (7.8 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (4.3 × 10^5^/mm^3^) (Table A1). The reticulocyte count of the female group administered identical combinations was approximately 1.9 times (8.0 × 10^5^/mm^3^; P≤0.01) that of the vehicle controls (4.3 × 10^5^/mm^3^) (Table A2).

Administration of combinations of AZT and pyrazinamide to male and female mice caused biologically and statistically significant increases in platelet counts of far greater magnitude than those observed subsequent to the administration of AZT alone. On day 4, significant changes in platelet counts were not observed in male mice administered combinations of AZT and pyrazinamide (Table A1). However, a significant thrombocytosis was observed on day 4 in some of the female groups receiving combination therapy. The platelet count of the female group treated with 200 + 1,500 mg/kg was approximately 1.1 times (1,275 × 10^3^/mm^3^; P≤0.05) that of the vehicle controls (1,144 × 10^3^/mm^3^) (Table A2). On day 30, the treatment-related thrombocytosis was distinctly dose related, with peak platelet counts in male and female mice administered the highest combination of AZT and pyrazinamide. The platelet count on day 30 of male mice administered 400 + 1,500 mg/kg was approximately 1.4 times (1,637 × 10^3^/mm^3^; P≤0.01) that of the vehicle controls (1,150 × 10^3^/mm^3^). The platelet count of female mice administered identical combinations was approximately 1.5 times (1,561 × 10^3^/mm^3^; P≤0.01) that of the vehicle controls (1,044 × 10^3^/mm^3^).

A dose-related thrombocytosis similar in magnitude to that described for day 30 was observed on day 60 in both male and female mice administered combinations of AZT and pyrazinamide. The platelet count on day 60 of male mice administered 400 + 1,500 mg/kg was approximately 1.6 times (1,510 × 10^3^/mm^3^; P≤0.01) that of the vehicle controls (949 × 10^3^/mm^3^) (Table A1). The platelet count of female mice administered an identical combination was approximately 1.5 times (1,515 × 10^3^/mm^3^; P≤0.01) that of the vehicle controls (1,010 × 10^3^/mm^3^) (Table A2).

The compound-related thrombocytosis persisted until the end of the study (days 92 to 95), with platelet counts of male and female mice administered combinations of AZT and pyrazinamide being greater than the platelet counts observed in mice treated with AZT alone. The platelet count of male mice administered 400 + 1,500 mg/kg was approximately 1.3 times (1,770 × 10^3^/mm^3^; P≤0.01) greater than that of the vehicle controls (1,347 × 10^3^/mm^3^) (Table A1). The platelet count of the female group administered identical doses was approximately 1.4 times (1,609 × 10^3^/mm^3^; P≤0.01) that of the vehicle controls (1,176 × 10^3^/mm^3^) (Table A2).

A slight leukopenia developed in male and female mice treated with AZT and pyrazinamide. In general, the magnitude of this leukopenia was slightly greater than that observed subsequent to the administration of AZT alone (Figures 6 and 7, Tables A1 and A2). The lowest mean WBC count on day 4 of male mice was observed in the group administered 400 + 1,500 mg/kg and was approximately 25% (5.15 × 10^3^/mm^3^; P≤0.01) less than that of the vehicle controls (6.87 × 10^3^/mm^3^). Evaluations of the corresponding differential data revealed slight declines in granulocytes as well as mononuclear cells. Similar changes were observed in female mice administered AZT and pyrazinamide combinations. The lowest WBC count on day 4 of female mice was observed in the group administered 400 + 1,000 mg/kg and was approximately 36% (5.22 × 10^3^/mm^3^; P≤0.01) less than that of the vehicle controls (8.11 × 10^3^/mm^3^). Decreases were observed in granulocytes as well as in mononuclear cell counts.

Alterations in WBC parameters were also observed on day 30. The lowest mean WBC value on day 30 of male mice was observed in the group administered 400 + 1,000 mg/kg and was approximately 13% (6.22 × 10^3^/mm^3^; P≤0.05) less than that of vehicle controls (7.18 × 10^3^/mm^3^) (Figure 6 and Table A1). Evaluation of the differential data revealed slight decreases in granulocytes and mononuclear cells. The leukopenia observed on day 30 in the female mice was distinctly dose related. The lowest WBC count of female mice was observed in the group administered 400 + 1,500 mg/kg and was approximately 34% (3.48 × 10^3^/mm^3^; P≤0.01) less than that of vehicle controls (5.24 × 10^3^/mm^3^) (Figure 7 and Table A2). Slight decreases were observed in both granulocyte and mononuclear cell counts.

The mild compound-related leukopenia was also observed on day 60 in male and female mice. The lowest WBC count in male mice on day 60 was observed in the group administered 200 + 1,000 mg/kg and was approximately 14% (5.23 × 10^3^/mm^3^; P≤0.05) less than that of the vehicle controls (6.11 × 10^3^/mm^3^) (Table A1). Slight decreases in granulocyte and mononuclear cell counts accompanied the decreased leukocyte values. Although not significant, the lowest WBC count on day 60 of female mice was observed in the group administered 400 + 1,500 mg/kg and was approximately 23% (4.00 × 10^3^/mm^3^) less than that of vehicle controls (5.18 × 10^3^/mm^3^) (Table A2). Slight declines in granulocyte and mononuclear cell counts were also observed.

The mild leukopenia continued through the end of the study (days 92 to 95), although none of the values were significant. The lowest WBC count observed at the end of the study in male mice was in the group administered 400 + 1,500 mg/kg and was approximately 20% (6.19 × 10^3^/mm^3^) less than that of the vehicle controls (7.70 × 10^3^/mm^3^) (Figure 6 and Table A1). The lowest WBC count of females was in the same high-dose combination group and was approximately 36% (3.16 × 10^3^/mm^3^) less than that of vehicle controls (4.90 × 10^3^/mm^3^) (Figure 7 and Table A2). Evaluation of the differential data revealed slight declines in granulocyte and/or mononuclear cell counts in both male and female mice.

## Necropsy Observations

Of 180 total mice in the core study groups, less than 10% had gross lesions of any type. None of the gross lesions were attributed to administration of AZT alone, pyrazinamide alone, or the combination of AZT and pyrazinamide. Four mice from the clinical pathology study groups died early and were the only mice in those groups necropsied. One of these four mice had a pale carcass, probably caused by anemia associated with cellular depletion of bone marrow resulting from administration of AZT and pyrazinamide at the highest dose concentrations. None of the other three mice had gross lesions attributed to administration of AZT and/or pyrazinamide.

## Histopathologic Observations

Suspected or actual target organs for microscopic lesions caused by the test chemicals included bone marrow, liver, and spleen (Table 2). Photomicrographs of representative compound-related lesions are shown in Plates 1 through 9 and summarized in Table 3.

TABLE 2 Incidence and Mean Severity of Histopathologic Alterations in Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations^a^

| Vehicle Control | 200 + 0 | 400 + 0 | 0 + 1,000 | 200 + 1,000 | 400 + 1,000 | 0 + 1,500 | 200 + 1,500 | 400 + 1,500
n | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10 | 10
Male
Bone marrow
Cellular depletion | 0 | 9 (1.1) | 9 (1.4) | 0 | 8 (1.3) | 9 (1.4) | 0 | 10 (1.5) | 9 (1.3)
Liver hepatocyte
Centrilobular glycogen depletion | 5 (2.2) | 6 (1.5) | 10 (2.0) | 10 (2.9) | 10 (2.9) | 10 (3.0) | 10 (2.4) | 10 (2.8) | 10 (2.7)
Spleen
Hematopoietic cell proliferation | 10 (1.4) | 10 (2.3) | 10 (2.4) | 10 (1.3) | 10 (2.2) | 10 (2.5) | 10 (1.6) | 10 (2.5) | 10 (2.4)
Female
Bone marrow
Cellular depletion | 0 | 6 (1.0) | 8 (1.4) | 0 | 10 (1.7) | 9 (1.7) | 0 | 10 (1.2) | 8 (1.6)
Liver hepatocyte
Centrilobular glycogen depletion | 2 (1.0) | 5 (1.2) | 7 (1.4) | 10 (2.7) | 10 (2.9) | 10 (2.6) | 10 (2.8) | 10 (2.4) | 9 (3.0)
Spleen
Hematopoietic cell proliferation | 10 (1.9) | 10 (2.9) | 10 (2.8) | 10 (1.9) | 10 (2.7) | 10 (3.0) | 10 (2.5) | 10 (2.6) | 10 (3.1)

a Daily gavage doses are given as AZT + pyrazinamide (mg/kg per day). Data are given as incidence (number of animals with lesion) followed by the mean severity (which is based on the numeric scale of 1 =minimal, 2= mild, 3 = moderate, 4=marked)

TABLE 3 Summary of Microscopic Examinations of Compound-Related Lesions in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Tissue | Magnification | Plate Number | Treatment-Related Lesions
0 + 0 | Liver | 400x | 1 | None
0 + 1,500 | Liver | 400x | 2 | Depletion, glycogen, hepatocyte, centrilobular (moderate)
0 + 0 | Spleen | 100x | 3 | None
400 + 0 | Spleen | 100x | 4 | Hematopoietic cell proliferation (moderate)
0 + 1,500 | Spleen | 100x | 5 | Hematopoietic cell proliferation (mild)
0 + 0 | Bone marrow | 100x | 6 | None
| | 200x | 7 | None
400 + 0 | Bone marrow | 100x | 8 | Cellular depletion (mild)
| | 200x | 9 | Cellular depletion (mild)

a AZT + pyrazinamide (mg/kg per day)

### Bone Marrow Lesions

Cellular depletion (depletion of hematopoietic cells) of bone marrow was observed in all male and female groups treated with AZT alone or AZT in combination with pyrazinamide. Criteria for severity grades of bone marrow lesions are as follows:

- Minimal - Depletion of approximately 5% or less of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available
- Mild - Depletion of approximately 6% to 20% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available
- Moderate - Depletion of approximately 21% to 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available
- Marked - Depletion of more than 50% of the hematopoietic cells of the bone marrow, based on examination of the metaphyseal region where available

None of the mice in the vehicle control groups and none of the mice treated with pyrazinamide alone developed cellular depletion of bone marrow. The mean severity of cellular depletion of bone marrow was significant (p≤0.01 and P≤0.05) in female groups treated with 200 + 1,000 mg/kg or 200 + 1,500 mg/kg. Mean severity grades in all other groups treated with combinations of AZT and pyrazinamide were similar to grades in their respective vehicle control groups. In general, the degree of severity of cellular depletion of the bone marrow corresponded with diminished erythrocyte counts observed in the peripheral circulation.

### Spleen Lesions

The spleen was examined routinely as a possible target organ, and hematopoietic cell proliferation was diagnosed in all spleens. Hematopoiesis occurs normally in the spleen of mice; thus, comparison of the splenic lesions among groups was, by necessity, a comparison only of mean severity, as the incidence was 100% in every group. Criteria for severity grades for hematopoietic cell proliferation follow:

- Minimal - approximately 15% or less of the red pulp occupied by hematopoietic cells of the types normally found in bone marrow
- Mild - approximately 16% to 50% of the red pulp occupied by hematopoietic cells of the types normally found in bone marrow
- Moderate - approximately 51% to 90% of the red pulp occupied by hematopoietic cells of the types normally found in bone marrow
- Marked - approximately 91% to 100% of the red pulp occupied by hematopoietic cells of the types normally found in bone marrow

Although slight increases in the mean severity were evident in all groups treated with AZT alone or in combination with pyrazinamide (Table 2), none of the severity scores were statistically significant when compared to the vehicle controls.

### Liver Lesions

Administration of AZT and pyrazinamide resulted in an increased incidence and/or severity of a cytoplasmic alteration in hepatocytes diagnosed as glycogen depletion. As glycogen does not stain with routine hematoxylin and eosin stains, this diagnosis represents a cytoplasmic alteration in hepatocytes manifested by diminished vacuolization. Criteria for severity grades of glycogen depletion of hepatocytes are as follows:

- Minimal - slight reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending not more than 1/3 to 1/2 the distance through the liver lobule from the central to portal veins
- Mild - almost complete reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending not more than 1/3 to 1/2 the distance through the liver lobule from the central to portal veins
- Moderate - almost complete reduction of the irregularly shaped cytoplasmic vacuoles that are characteristic of the presence of glycogen in hepatocytes in areas surrounding the central veins, such areas usually extending 1/2 or more of the distance through the liver lobule from the central to portal veins

A statistical analysis was performed on the mean severity grades of glycogen depletion in hepatocytes (Table 4). In male and female mice, the administration of 200 or 400 mg/kg AZT alone resulted in increased incidences of glycogen depletion but did not affect the severity of the lesion. The administration of 1,000 or 1,500 mg/kg pyrazinamide resulted in increases in both the incidences and severities (p≤0.01) of glycogen depletion in male and female mice; these effects were not enhanced by the coadministration of AZT. The degree of severity appeared to peak with 1,000 mg/kg, as severity grades in male and female groups treated with 1,000 or 1,500 mg/kg pyrazinamide alone or in combination with AZT were all similar.

## Sperm Motility and Vaginal Cytology Evaluations

Pyrazinamide alone had a significant effect on left caudal and epididymal weights and spermatid heads per testis (Appendix C). Left caudal weights (P≤0.01) and spermatid heads per testis (P≤0.01) were significantly decreased at 1,500 mg/kg, while left epididymal weights were significantly decreased (P≤0.05) at 1,000 and 1,500 mg/kg. Left testicular weights were affected by AZT alone and pyrazinamide alone. Left testicular weights were significantly decreased (P≤0.01) in groups administered 400 + 1,000 mg/kg or 400 + 1,500 mg/kg. Sperm motility was significantly decreased (P=0.048) by an interaction of AZT and pyrazinamide.

The average estrous cycle length and estrual cycle were not affected by AZT alone, pyrazinamide alone, or combinations of AZT and pyrazinamide.

TABLE 4 Statistical Analysis of Mean Severity of Glycogen Depletion of Hepatocytes in Male and Female Mice in the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

Dose^a^ | Mean Severity^b^ | Standard Error | Ratio^c^
Male
0 + 0 | 1.10 | 0.41 | —
0 + 1,000 | 2.90^**^ | 0.10 | 2.64
0 + 1,500 | 2.40 | 0.16 | 2.18
200 + 0 | 0.90 | 0.28 | —
200 + 1,000 | 2.90^**^ | 0.10 | 3.22
200 + 1,500 | 2.80^**^ | 0.13 | 3.11
400 + 0 | 2.00 | 0.15 | —
400 + 1,000 | 3.00^**^ | 0.00 | 1.50
400 + 1,500 | 2.70^**^ | 0.15 | 1.35
Female
0 + 0 | 0.20 | 0.13 | —
0 + 1,000 | 2.70^**^ | 0.15 | 13.50
0 + 1,500 | 2.80^**^ | 0.13 | 14.00
200 + 0 | 0.60 | 0.22 | —
200 + 1,000 | 2.90^**^ | 0.10 | 4.83
200 + 1,500 | 2.40^**^ | 0.22 | 4.00
400 + 0 | 1.00 | 0.26 | —
400 + 1,000 | 2.60^**^ | 0.22 | 2.60
400 + 1,500 | 2.70^**^ | 0.30 | 2.70

** Significantly different from the vehicle control group (P≤0.01) by Jonckheere’s test

a Daily gavage doses of AZT + pyrazinamide (mg/kg per day); n= 10

b Mean severity is based on numerical scale of 1 = minimal, 2=mild, 3 = moderate, 4 = marked

c Dosed group mean/vehicle control group mean

PLATE 1 Liver of a vehicle control female B6C3F_1_ mouse showing no lesions. H&E; 400X.

PLATE 2 Liver of a female B6C3F_1_ mouse given 1,500 mg pyrazinamide per kg body weight per day by gavage for 13 weeks showing moderate depletion of glycogen in hepatocytes in the centrilobular zone. Hepatocyte remnants, apoptotic bodies (arrows), are visible near the central vein. H&E; 400 x

PLATE 3 Spleen of a vehicle control male B6C3F_1_ mouse showing no lesions H&E-100X

PLATE 4 Spleen of a male B6C3F_1_ mouse given 400 mg AZT per kg body weight per day by gavage for 13 weeks showing moderate cell proliferation. H&E; 100 X

PLATE 5 Spleen of a female B6C3F_1_ mouse given 1,500 mg pyrazinamide per kg body weight per day by gavage for 13 weeks showing mild hematopoietic cell proliferation. H&E; 100 X

PLATE 6 Bone marrow (femur) of a vehicle control female B6C3F_1_ mouse showing no lesions. H&E; 100 x

PLATE 7 Bone marrow (femur) of a vehicle control female B6C3F_1_ mouse showing no lesions. H&E; 200 x

PLATE 8 Bone marrow (femur) of a female B6C3F_1_ mouse given 400 mg AZT per kg body weight per day by gavage for 13 weeks showing mild cellular depletion. H&E; 100 x

PLATE 9 Bone marrow (femur) of a female B6C3F_1_ mouse given 400 mg AZT per kg body weight per day by gavage for 13 weeks showing mild cellular depletion. H&E; 200 X