# Materials and Methods

## Procurement and Characterization of Chemicals

3′-Azido-3′-deoxythymidine (AZT; lot 1401-R-8) was manufactured by Raylo Chemicals (Edmonton, Alberta) and supplied as a powder. Pyrazinamide (lot 98-6-4) was manufactured by Aldrich Chemical Co. (Milwaukee, WI) and supplied as a powder. Methylcellulose (lot 876672) was obtained as powder from Fisher Scientific Company (Pittsburgh, PA).

The relative purity of AZT was determined by high-performance liquid chromatography to be 100%. The purity of the pyrazinamide was estimated to be 99.4% by high-performance liquid chromatography. Lot 876672 of methylcellulose met the USP specifications for all analyses and was considered to be suitable for use as a dosing vehicle. The control vehicle used in this study was an aqueous solution containing 0.5% methylcellulose.

## Dose Formulations

The dosing vehicle was prepared by mixing methylcellulose with heated deionized water and then diluting with water to form a 0.5% solution, which was allowed to cool. AZT, pyrazinamide, or combination of the two drugs was then mixed with the dosing vehicle until a homogeneous suspension was obtained to give the required concentrations (Table 1).

Stability studies indicated that the dose formulations were stable for 30 days when stored refrigerated or at room temperature. Dose formulations for this study were stored refrigerated, protected from light, and used within 22 days. Samples at each dose concentration from the initial, mid point, and final dose formulations were analyzed by high-performance liquid chromatography for concentration. The concentrations of AZT ranged from 93.5% to 102% of the target concentrations; concentrations of pyrazinamide were 101% to 108% of the target concentrations. Residual dosing formulations taken from the animal room after dosing with the initial and final mixes were also analyzed. Concentrations of the residual formulations were within 10% of the target concentration, except one AZT sample (70.7%) and four pyrazinamide samples (51.2% to 121%).

## Study Design

Mice were obtained from an NIEHS/NTP colony at Taconic Laboratory Animals and Services (Germantown, NY) and were approximately 6 weeks old when placed on study. The mice were housed five males or five females per cage during quarantine before randomization. After randomization, males were individually housed, and females continued to be housed five per cage.

The mice were housed in polycarbonate cages with solid bottoms and sides. Average temperature in the animal rooms was 71.0° F, with a standard deviation of 0.9° F; average relative humidity was 51.4%, with a standard deviation of 7.4%.

At terminal sacrifice, blood samples were collected from five male and five female sentinel animals as part of the animal disease screening program. Results indicated all animals were free of viral antibodies.

AIDS patients frequently receive combination therapy with pyrazinamide and AZT to treat tuberculosis, which is one of the complicating opportunistic infections in these immunologically suppressed individuals. At the present time, no acceptable alternatives to animal models provide adequate toxicity information regarding this combination therapy. Grossett et al. (1992) reported eradication of tuberculosis in Swiss (CD-1®) mice with 150 mg pyrazinamide/kg body weight per day. In a previous reproductive toxicity study of pyrazinamide, no toxicity was observed at doses up to 1,200 mg pyrazinamide/kg body weight per day (eight times the therapeutic dose) for 30 days (NIEHS, 1997). Therefore, doses below (1,000 mg/kg) and above (1,500 mg/kg) the nontoxic dose of pyrazinamide were selected for this study. The AZT dose concentrations for this study were based on results of previous toxicity studies conducted in mice, which demonstrate that measurable evidence of toxicity will be obtained at 200 and 400 mg AZT/kg body weight per day. Even though the high dose of pyrazinamide selected for this study was 10 times the therapeutic dose, based on the previous study (NIEHS, 1997) it may not cause measurable toxicity; therefore, doses of AZT less than 200 mg/kg, which may not cause consistently measurable toxicity, were not included to evaluate combination toxicity with pyrazinamide.

A brief summary of the study design is provided in Table 1. The study was conducted in B6C3F_1_ mice because this strain is routinely utilized for toxicity evaluations of this type by the NIEHS/NTP. The oral route of administration was selected because this is the clinically relevant route used in humans. Combinations of AZT and pyrazinamide were administered by gavage as a single dose formulation. Total daily dose volumes of 20 mL/kg were divided into two equal doses of 10 mL/kg administered approximately 6 hours apart. There were 20 male and 20 female mice per dose group. Core study animals (10 per group) were dosed until the day prior to sacrifice (91 to 94 days). Clinical pathology study animals (10 per group) were dosed until day 59. All mice were observed twice daily (morning and afternoon) for mortality/moribundity.

On study days 4, 30, and 60 (clinical pathology study animals) or prior to terminal sacrifice on study days 92 to 95 (core study animals), blood was drawn for hematology determinations. Vaginal cytology evaluations were conducted on all core study females on days 76 to 87, and sperm count, function, and motility were assessed on core study males on days 92 to 95. All surviving clinical pathology study animals were euthanatized on day 60 using 100% CO_2_ and discarded; all surviving core study animals were sacrificed on days 92 to 95 using 100% CO_2_. A complete gross necropsy was conducted on all core study animals and early death clinical pathology study animals.

### Clinical Pathology

All blood samples were collected from the retroorbital sinus under CO_2_/O_2_ anesthesia into tubes containing EDTA. Animals were selected in random order for blood collection, and samples were analyzed in the order collected.

Erythrocyte, platelet, and leukocyte counts; hematocrit; hemoglobin concentration; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; and leukocyte differentials were determined on whole blood using a Technicon H·1™ automated hematology analyzer. Reticulocyte counts were conducted using a Coulter Model Elite Flow Cytometer™. Blood smears were prepared to manually verify leukocyte differentials and platelet morphology if necessary.

### Vaginal Cytology and Sperm Function Evaluations

Samples of vaginal fluid were collected from females using a medicine dropper moistened with 0.9% saline. Samples from 12 consecutive days per group were placed on two slides per animal, which were evaluated for relative frequency of estrous phases and the estrous cycle length.

Sperm motility was evaluated at necropsy in the following manner. The left epididymis was isolated and weighed. The tail of the epididymis (cauda epididymis) was then removed from the epididymal body (corpus epididymis). Modified Tyrode’s buffer was applied to slides, and a small incision was made at the border of the cauda epididymis. The sperm effluxing from the incision were dispersed in the buffer on the slides, and the numbers of motile and nonmotile spermatozoa were counted for five fields per slide by two observers.

Following completion of sperm motility estimates, each left cauda epididymis was placed in buffered neutral saline solution. Caudae were finely minced, and the tissue was incubated in the saline solution and then heat fixed at 65°C. Sperm density was then determined microscopically with the aid of a hemocytometer. To quantify spermatogenesis, a testicular spermatid head count was determined by removing the tunica albuginea and homogenizing the left testis in phosphate-buffered saline containing 10% dimethyl sulfoxide. Homogenization-resistant spermatid nuclei were counted with a hemocytometer.

### Histopathology

Necropsy was performed on all core study animals and early death clinical pathology study animals. The heart, right kidney, liver, lungs, right testis, and thymus were weighed. Histopathology was conducted on the tissues listed in Table 1. The tissues were preserved in the appropriate fixative, trimmed to a maximum thickness of 0.3 cm for processing, embedded in paraffin, sectioned at 4 to 6 μm, stained with hematoxylin and eosin (testes were stained with PAS), and examined by light microscopy.

TABLE 1 Experimental Design and Materials and Methods for the 13-Week Toxicity Study of AZT and Pyrazinamide Combinations

Study Laboratory; Southern Research Institute, Birmingham, AL
Strain and Species; B6C3F_1_ mice
Animal Source; Taconic Laboratory Animals and Services, Germantown, NY
Time Held Before Study; 11 or 12 days
Average Age When Study Began; 42 or 43 days
Date of First Dose; August 30, 1993
Duration of Dosing; Day 1 through day prior to sacrifice
Date of Last Dose; December 1, 1993
Necropsy Dates; November 29 to December 3, 1993
Average Age at Necropsy; 133 days
Size of Study Groups; 10 males and 10 females
Method of Animal Distribution; Animals were assigned to groups using a stratified weight method and then assigned to study groups in random order
Animals per Cage; Five males or five females per cage during quarantine, then one male per cage and five females per cage after randomization
Method of Animal Identification; Microchip implant
Diet; NIH-07 pelleted feed, available ad libitum
Water; Tap water (Birmingham, AL), available ad libitum
Cages; Polycarbonate cages with solid bottoms and sides
Bedding; Heat-treated hardwood chips (Sani-Chips®, P.J. Murphy Forest Products Corporation. Montville, NJ)
Cage Filters; Reemay® spun-bonded polyester (Andico, Birmingham, AL)
Racks; Stainless steel (Lab Products, Maywood, NJ)
Animal Room Environment; Temperature: 71.0° ± 0.9° F; Relative humidity: 51.4% ± 7.4%; Fluorescent light: 12 hours fluorescent light/day; Room air: minimum of 10 changes/hour
Doses; Daily doses in an aqueous solution of 0.5 % methylcellulose by gavage:; 0 mg AZT + 0 mg pyrazinamide per kg body weight per day; 200 mg AZT + 0 mg pyrazinamide per kg body weight per day; 400 mg AZT + 0 mg pyrazinamide per kg body weight per day; 0 mg AZT + 1,000 mg pyrazinamide per kg body weight per day; 200 mg AZT + 1,000 mg pyrazinamide per kg body weight per day; 400 mg AZT + 1,000 mg pyrazinamide per kg body weight per day; 0 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; 200 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; 400 mg AZT + 1,500 mg pyrazinamide per kg body weight per day; All doses were administered daily (7 days per week) in two equal doses approximately 6 hours apart.
Type and Frequency of Observations; Mortality/moribundity: twice daily; Clinical findings: once weekly; Body weights: once weekly
Method of Sacrifice; CO_2_ asphyxiation
Necropsy; Complete necropsies were performed on all core study animals and early death clinical pathology study animals. The heart, right kidney, liver, lungs, right testis, and thymus were weighed.
Histopathology; The following tissues were examined: brain, femur, gross lesions, heart and aorta, kidneys, liver, lungs and bronchi, mandibular and mesenteric lymph nodes, ovaries, spleen, testes with epididymis, thymus, tissue masses.
Clinical Pathology; Hematology evaluations were conducted on all clinical pathology study animals on days 4, 30, and 60 and on all core study animals at terminal sacrifice. The parameters evaluated included erythrocyte, reticulocyte, and platelet counts; hematocrit; hemoglobin concentration; mean cell hemoglobin; mean cell volume; mean cell hemoglobin concentration; leukocyte counts and differentials; and platelet morphology (if necessary).
Sperm Function Evaluation; Sperm samples were collected from all core study males at terminal sacrifice. The left epididymis and cauda epididymis were weighed. The parameters evaluated included spermatid heads, spermatid counts, and motility.
Vaginal Cytology Evaluation; Vaginal fluid samples were collected from all core study females on days 76 to 87. The parameters evaluated included relative frequency of estrous phases and the estrous cycle length.

## Statistical Methods

Group means and standard deviations were calculated for hematology parameters and for final mean body and organ weights. Organ-weight-to-body-weight ratios were also calculated. Final mean body weights, mean organ weights, and organ-weight-to-body-weight ratios for each dosed group were compared to those of the control group by a two-tailed Student’s t-test. The standard deviations used in the t-tests were obtained by pooling the individual values for the control and dosed groups. Hematology data were evaluated using Dunnett’s (1955) test.

Severity grades for lesions in liver, spleen, and bone marrow were analyzed for interaction using two-way analysis of variance. If a significant interaction between AZT and pyrazinamide was observed, mean values were plotted to graphically display the interaction between the two chemicals. In the absence of interaction, vehicle control and dosed group means were compared using either Williams’ (1971, 1972) or Dunnett’s (1955) multiple comparison procedures. The choice between the two tests was based on evidence of a dose-related trend in the data as determined by Jonckheere’s test (Jonckheere, 1954). Williams’ and Dunnett’s tests were also used to assess the significance of differences between vehicle control and dosed group responses for male final mean body weights and reproductive parameters. Jonckheere’s test was used to assess the significance of dose-response trends. Trend sensitive tests were used when Jonckheere’s test was significant at P≤0.01. If the P value from Jonckheere’s test for a dose-related trend was P≥0.10, Dunn’s (1964) test was used. If the P value was less than 0.10, Shirley’s (1977) test was used. The outlier test of Dixon and Massey (1951) was employed to detect extreme values. Implausible values, extreme values from animals that were suspected of being sick due to causes other than treatment, and values that were indicated to be inadequate due to measurement problems were eliminated from analysis.

Treatment effects on vaginal cytology data were investigated by applying a multivariate analysis of variance (using Wilke’s Criterion [Stevens, 1986] as the test statistic) to test for the simultaneous equality of measurements across dose concentrations. Because the data are proportions (the proportion of the observation period that an animal was in a given estrous phase), an arcsine transformation was used to bring the data into closer conformance with the normality assumptions required for the multivariate analysis of variance.