# Introduction

AIDS is a lethal multi-system disease that has become a major public health problem since its recognition in 1981 (Gottlieb et al., 1981; Masur et al., 1981; Siegle et al., 1981). The etiological agent of AIDS is a retrovirus now referred to as HIV (Coffin, 1986). To date, the most effective single agent in the treatment of HIV has been the first dideoxynucleoside analogue used in clinical trials, zidovudine (3′-azido-3′-deoxythymidine, AZT, Retrovir, azidothymidine, compound S, BW A509U, CAS No. 30516-87-1), commonly referred to as AZT (Vince et al., 1988; Amin, 1989).

AZT therapy produces numerous beneficial effects in AIDS patients, including decreases in morbidity and increases in lifespan (Amin, 1989; Jeffries, 1989). The most important adverse effects of AZT are anemia and granulocytopenia, which are believed to reflect bone marrow toxicity (Richman, 1988; Amin, 1989). Two types of anemia may occur with AZT therapy: macrocytic megaloblastic anemia and normocytic normochromic anemia.

Several subacute and subchronic rodent toxicity studies have demonstrated that the primary toxicity of AZT is myelosuppression. Male Swiss (CD-1®) mice were administered 100, 250, 500, or 1,000 mg/kg body weight by gavage for 30 days (Mansuri et al., 1990). No mortality or body weight effects were evident from AZT treatment. Erythropenia and increased mean cell volume were observed at all doses, and anemia was observed at the 1,000 mg/kg dose. Pathologic findings in the AZT-treated mice were consistent with the hematologic results and included lymphoid depletion, reticuloendothelial hyperplasia in spleen and thymus, and bone marrow hypocellularity.

In a 14-week subchronic study (NTP, 1999), B6C3F_1_ mice were treated with 0, 25, 50, 100, 400, or 1,000 mg AZT/kg body weight in 0.5% methylcellulose by gavage. All doses were administered twice daily as one half of the total daily dose. On day 5, statistically significant dose-related decreases were observed in reticulocyte counts in both males and females. Dose-related anemia was evident on days 23 and 93. To evaluate the ability of treated animals to reverse any compound-related effects when treatment is stopped, additional groups of mice received AZT in 0.5% methylcellulose at doses of 0, 50, 400, or 1,000 mg/kg twice daily by gavage for 14 weeks and then were held without additional treatment for 4 weeks. Improvement of hematology parameters indicated recovery of the bone marrow after treatment stopped. An apparently nontoxic, treatment-related clinical finding that affected AZT-treated B6C3F_1_ mice was a darkening of the skin on the tail, feet, and muzzle. AZT alone, when administered by gavage to B6C3F_1_ mice at 100, 200, or 300 mg/kg per day for 13 weeks, caused hematopoietic toxicity with dose-related bone marrow suppression, macrocytic anemia, and thrombocytosis (Rao et al., 1998).

Oral bioavailability of AZT was determined in female B6C3F_1_ mice by comparison of the area under the curve obtained from an oral dose to that of an intravenous dose (Trang et al., 1993). Bioavailability was found to be 0.86, 0.78, and 0.97 for the 15, 30, and 60 mg/kg oral doses. The mean elimination half-life values ranged from 17.3 to 19.9 minutes for the three intravenous doses and from 16.5 to 21.9 minutes for the three oral doses. Based on these results, the internal dose of AZT was linear and dose proportional over the oral-dose concentration range administered.

Standard teratology studies of AZT have been performed in rats and rabbits (Ayers, 1988). Rats were dosed orally with 125 to 500 mg/kg on gestation days 6 to 15. No fetal toxicity or teratogenicity was found. Fetal AZT concentrations 30 minutes post-dosing were 61 μg/g, or 76 times the antiviral ID_50_ (inhibitory dose for 50% of the viral population being tested). Rabbits were orally dosed at 75 to 500 mg/kg on gestation days 6 to 18. The high dose caused an increased incidence of late resorptions with no evidence of teratogenicity, and no fetal toxicity was found. Fetal AZT concentrations 30 minutes post-dosing were 40.2 μg/g, or 50 times the human antiviral ID_50_.

Female Wistar rats were dosed three times orally with 100 mg/kg AZT at 5-hour intervals on gestation day 10 for a total dose of 300 mg/kg (Greene et al., 1990). No adverse effects on maternal weight gain, feed consumption, fertility, hematologic parameters or growth or survival of offspring were observed. AZT concentration measurements 30 minutes after the last dose were 62.6 μg/mL in maternal plasma and 21.1 μg/g in fetal tissue.

Studies in C_3_H/He mice concluded that AZT has a direct toxic effect on the developing mouse embryo (Toltzis et al., 1991). Female mice were exposed to 0, 0.25, 0.5, or 2.5 mg AZT/mL in the drinking water for 8 weeks during mating and throughout gestation. All AZT groups had fewer pregnant mice per group, fewer pups per litter, and increased resorptions per mouse. Dose-related embryolethality was observed.

Because AIDS is a disease of immune suppression, the majority of AIDS patients actually die from characteristic opportunistic infections (Hardy, 1991; Harkins and Herriot, 1992), and the treatment of AIDS is increasingly one of combination therapy of anti-HIV drugs and antimicrobial drugs (Goldschmidt and Dong, 1992). Tuberculosis (TB) is one of the opportunistic diseases leading to mortality in AIDS patients (Nolan, 1992). AIDS patients with TB receive combination therapy with AZT and antituberculosis drugs. Treatment for TB involves combination therapy with multiple antibacterial agents in order to eliminate the strains of organisms inducing TB, including those resistant to isoniazid, the primary drug used in treating TB.

The standard treatment regimen is isoniazid (300 mg/day), rifampin (600 mg/day or 450 mg/day for persons weighing less than 50 kg), and pyrazinamide (20 to 30 mg/kg per day) for the first 2 months of treatment. Isoniazid and rifampin are continued for another 7 months, for a total therapy duration of 9 months (CDC, 1987; Barnes et al., 1991). The inclusion of pyrazinamide in treatment regimens has shortened the length of therapy to 6 months (East and Central African/British Medical Research Council, 1986). Pyrazinamide is the synthetic pyrazine analogue of nicotinamide. The daily dose for adults is 20 to 35 mg/kg orally, given in three or four equally spaced doses. The maximum quantity to be administered is 3 g per day, regardless of body weight.

Pyrazinamide is well absorbed from the gastrointestinal tract and is widely distributed throughout the body. The oral administration of 1 g produces plasma concentrations of about 45 μg/mL at 2 hours and 10 μg/mL at 15 hours. The drug is excreted primarily by renal glomerular filtration; urinary concentrations are 50 to 100 μg/mL for several hours after a single dose. Pyrazinamide is hydrolyzed to pyrazinoic acid and subsequently hydroxylated to 5-hydroxypyrazinoic acid, the major excretory product (Weiner and Tinker, 1972). Grossett et al. (1992) reported that 150 mg/kg pyrazinamide (considered to be a therapeutic dose) administered by gavage to female Swiss (CD-1^®^) mice resulted in serum concentrations similar to those of humans receiving pyrazinamide therapy.

Injury to the liver is the most common and serious side effect of pyrazinamide. When a dose of 3 g per day (40 to 50 mg/kg body weight) is orally administered, signs and symptoms of hepatic disease appear in about 15% of patients, with jaundice in 2% to 3% of patients, and death due to hepatic necrosis occurring in rare instances (Mandell and Sande, 1990). Mild and transient elevations of the plasma alanine and aspartate aminotransferases are the earliest abnormalities produced by the drug and occur approximately 2 weeks after initiation of therapy (Ramakrishnan et al., 1968). Baron and Bell (1974) have noted that such transient asymptomatic increases in the serum hepatic enzyme concentrations are also common during the early weeks of antituberculosis chemotherapy with other drugs, and these usually return to normal without interrupting or altering the regimen and are not clinically important.

Hepatotoxicity and nephrotoxicity occurred in male Wistar rats following the administration of 2.5 g/kg of pyrazinamide by gavage in 10% gum arabic (Zitkova et al., 1983). Bederka et al. (1975) have reported an LD_25_ for pyrazinamide in young adult female Swiss albino and Charles River mice (20 to 32 g) of 705 mg/kg following intraperitoneal administration in dimethyl sulfoxide. The LD_50_ data for pyrazinamide reported in the Registry of Toxic Effects of Chemical Substances are as follows: mouse intraperitoneal, 1,680 mg/kg; mouse subcutaneous, 2,793 mg/kg (RTECS, 1983).

Roman and Georgian (1977) studied the comparative cytogenetic effects of para-aminosalicylic acid sodium sait, pyrazinamide, and rifampin in human peripheral blood cultures. The structural chromosomal lesions were randomly distributed between the different chromosome groups of the human karyotype; nearly 20% to 30% of affected cells had more than one lesion per metaphase. In the treatments with sodium para-aminosalicylate and pyrazinamide, the analysis of the frequencies of the cells carrying chromosomal aberrations and of the chromosomal lesion types indicated a dose-response correlation. The in vitro studies indicate a potential genetic hazard in the use of these drugs.

## Study Rationale

The objective of this study was to obtain controlled laboratory data on the toxicity of AZT and pyrazinamide combination therapy with subchronic exposure. Male and female B6C3F_1_ mice were dosed orally with AZT (200 or 400 mg/kg per day) alone, pyrazinamide (1,000 or 1,500 mg/kg per day) alone, or with combinations of AZT and pyrazinamide for up to 94 days. Mice were evaluated for clinical findings, mean body weights, sperm function, vaginal cytology, and clinical pathology parameters. Selected animals were necropsied and subjected to histopathologic evaluations.